# References

Allen SM, Mor V. The prevalence and consequence of unmet need: Contrasts between older and younger adults with disabilities. Medical Care. 1997;35:1132-1148. [pmid: 9366892].
American Association of People with Disabilities. About AAPD. Washington DC. American Association of People with Disabilities. 2004. www.aapd-dc.org/docs/info.html#top.
Americans with Disabilities Act of 1990 (ADA). P.L. 101–336. July 26. Title 42 U.S.C. 12101 et seq. U.S. Statutes at Large. 1990;104:327-378.
Barnard D. Toombs SK, Barnard D, Carson RD, editors. Chronic illness and the dynamics of hoping. Chronic Illness: From Experience to Policy. Bloomington IN. Indiana University Press. 1995.
Braddock D, Parish SL. Braddock D, editor. An institutional history of disability. Disability at the Dawn of the 21st Century and the State of the States. Washington DC. American Association on Mental Retardation. 2002:3-61.
Brandt EN, Pope AM, editors. Enabling America: Assessing the Role of Rehabilitation Science and Engineering. Washington DC. National Academy Press. 1997.
Branigan M, Stewart DE, Tardif G, Veltman A. Perceptions of primary healthcare services among persons with physical disabilities; Part 2: Quality issues. Medscape General Medical. April 06. 2001.
Calkins E, Boult C, Wagner E, Pacala JT. New Ways To Care for Older People: Building Systems Based on Evidence. New York NY. Springer. 1999.
Center J, Beange H, McElduff A. Mentally retarded individuals: A population at risk?. Medicine and Science in Sports and Exercise. 1998;23(5):586-593.
Centers for Disease Control and Prevention. Unpublished analysis of Behavioral Risk Factor Surveillance System 2001. 2004.
Centers for Disease Control and Prevention. Summary health statistics for the U.S. population, National Health Interview Survey, 2002. National Vital Health Statistics Reports. 2004;10(220).
Centers for Disease Control and Prevention, National Center for Health Statistics. National Vital Health Statistics Reports. Table 11. December 19. 2002;51(3).
Centers for Disease Control and Prevention, National Center for Health Statistics. State and Local Area Integrated Telephone Survey: the Children with Special Health Care Needs Module. 2000. www.cdc.gov/hchs/about/major/slaits/cshcn.htm.
Centers for Disease Control and Prevention. Prevalence of disability and associated health conditions among adults – United States 1999. Morbidity and Mortality Weekly Report. 2001;50(7):120-125. [pmid: 11393491].
Cherry Engineering Support Services, Inc. Federal Statutory Definitions of Disability Prepared for the Interagency Committee on Disability Research. 2003. www.icdr.us/documents/. Accessed on-line, 2004.
Clancy CM, Andresen EM. Meeting the health care needs of persons with disabilities [commentary]. Milbank Quarterly. 2002;80(2):381-91. [pmid: 12101877].
Compton DM, Eisenman PA, Henderson HL. Exercise and fitness for persons with disabilities. Sports Medicine. 1989;7(3):150-162. [pmid: 2525270].
Coyle CP, Santiago MC. Healthcare utilization among women with physical disabilities. Medscape Women’s Health eJournal. 2000;7(4). www.med-scape.com/viewarticle/433156.
DeJong G, Palsbo SE, Beatty PW, Jones GC, Kroll T, Neri MT. The organization and financing of health services for individuals with disabilities. Milbank Quarterly. 2002;80(2):261-301. [pmid: 12101873].
Fann JR, Katon WJ, Uomoto JM, Esselman PC. Psychiatric disorders and functional disability in outpatients with traumatic brain injuries. American Journal of Psychiatry. 1995;152:1493-1499. [pmid: 7573589].
Federal Interagency Forum on Age-Related Statistics. Older Americans 2004. Key Indicators of Well-being. Washington DC. US Government Printing Office. 2004.
Francis LP, Silvers A, editors. Americans with Disabilities: Exploring Implications of the Law for Individuals and Institutions. New York NY. Routledge. 2000.
Heinemann AW, Doll MD, Armstrong KJ, Schnoll S, Yarkony GM. Sbustance abuse and receipt of treatment by persons with long-term spinal cord injuries. Archives of Physical Medicine and Rehabilitation. 1991;72:482-487. [pmid: 2059120].
Henry J. Kaiser Family Foundation. Americans’ Views of Disability. A Kaiser Health Poll Report. May/June. 2004. www.kff.org/healthpollreport/.
Henry J. Kaiser Family Foundation. Understanding the Health-care Needs and Experiences of People with Disabilities. Findings from a 2003 Survey. Menlo Park CA. The Henry J. Kaiser Family Foundation. December. 2003.
Hough J. Estimating the Health Care Utilization Costs associated with People with Disabilities: Data from the 1996 Medical Expenditure Panel Survey (MEPS). Annual meeting of the Association for Health Services Research. Los Angeles, CA. 2000.
Hough J. Simeonsson RJ, McDevitt LN, editors. Disability and Health. A national public health agenda. Issues in Disability and Health. The Role of Secondary Conditions and Quality of Life. Chapel Hill NC. University of North Carolina Press. 1999.
Iezzoni LI, O’Day BL, Killeen M, Harker H. Communicating about health care: Observations from persons who are deaf or hard of hearing. Annals Internal Medicine. 2004;140:356-363.
Iezzoni IL. When Walking Fails: Mobility Problems of Adults with Chronic Conditions. Berkeley and New York. University of California Press and the Milbank Memorial Fund. 2003.
Iezzoni LI, Davis RB, Soukup J, O’Day B. Satisfaction with quality and access to health care among people with disabling conditions. International Journal on Quality of Health Care. 2002;14:369-381.
Institute on Disability and Development. Proceedings of Changing Concepts of Health and Disability: State of the Science Conference and Policy Forum 2003. Portland OR. Oregon Health and Science University. 2003.
Jackson K. Healthcare for people with disabilities: Making it through the maze. Social Work Today. July–August. 2004:12-16.
Janssen TW, van Oers CA, van der Woude LH, Hollander AP. Physical strain in daily life of wheel chair users with spinal cord injuries. Medicine and Science in Sports and Exercise. 1994;26(6):661-670. [pmid: 8052104].
Jones KE, Tamari IE. Making our offices universally accessible: Guidelines for physicians. Canadian Medical Association Journal. 1997;156(5):647-656. [pmid: 9068570].
Kaplan SH, Sullivan LM. Maximizing the quality of the physician-patient encounter. Journal of General Internal Medicine. 1996;11(3):187-188. [pmid: 8667100].
Kinne SK, Patrick DL, Doyle DL. Prevalence of secondary conditions among people with disabilities. American Journal Public Health. 2004;94(3):443-445.
Krause JS, Bell RB. Simeonsson RJ, McDevitt, editors. Measuring quality of life and secondary conditions: Experiences with spinal cord injury. Issues in Disability and Health: The Role of Secondary Conditions and Quality of Life. Chapel Hill NC. University of North Carolina Press. 1999.
Krahn G. Changing concepts in health, wellness and disability. Institute on Disability and Development. Proceedings of Changing Concepts of Health and Disability: State of the Science Conference and Policy Forum 2003. Portland OR. Oregon Health and Science University. 2003.
LaPlante MP, Kaye HS, editors. Trends in Disability and Their Causes: Proceedings of the Fourth National Disability Statistics and Policy Forum. Washington DC. National Institute on Disability and Rehabilitation Research, US Department of Education. 1998.
Leigh JP, Markowitz S, Fahs M, Shin C, Landrigan PJ. Occupational injury and illness in the United Sttes: Estimates of costs, morbidity, and mortality. Archives of Internal Medicine. 1997;157:1557-1568. [pmid: 9236557].
Luckasson R, Borthwick-Duffy S. Mental Retardation: Definition, Classification, and Systems of Support. 10th ed. Washington DC. American Association on Mental Retardation. 2002.
Marge M. Health promotion for persons with disabilities: Moving beyond rehabilitation. Am J Health Promotion. 1988;2(4):29-44.
Masuda S. Women with Disabilities: We Know What We Need To Be Healthy. Vancouver BC. British Columbia Centre of Excellence for Women’s Health. 1999.
McMillen JS, Simeonsson RJ, McDevitt L. Simeonsson RJ, McDevitt, editors. Preventing secondary conditions and promoting health, well being and quality of life. Issues in Disability and Health: The Role of Secondary Conditions and Quality of Life. Chapel Hill NC. University of North Carolina Press. 1999.
McNeil JM. Americans with Disabilities. Household Economic Studies, Current Population Reports. 1. 20. February. 2001:P70-73. www.census.gov/prod/2001pubs/p70-73.pdf.
McNeil JM. Americans with disabilities 1994–1995. Current Populations Report. August. 1997;P7061:3-6.
McNeil JM, Binette J. Prevalence of Disabilities and Associated Health Conditions Among Adults— United States, 1999. Morbidity and Mortality Weekly Report. 2001;50(7):120-125. [pmid: 11393491].
Melnikova N, Hough J, Lollar D. Osteoporosis among women with physical disabilities: Risk factors and protective factors. Paper presented at 126th annual meeting of the American Public Health Association. November 17, 1998.
Moore D. Wolkstein E, editor. Plenary 1: Introduction to the issues. Proceedings of the Second National Conference on Substance Abuse and Coexisting Disabilities. Dayton OH. Wright Sate University School of Medicine. 2002.
Moore D, Li L. Prevalence and risk factors of illicit drug use by people with disabilities. American Journal on Addictions. 1998;7:93-102. [pmid: 9598213].
National Heart, Lung and Blood Institute. Facts About Cystic Fibrosis. Bethesda MD. National Institutes of Health. November. 1995. www.healingwell.com/library/cysticfibrosis/info2.asp.
National Institute of Child Health and Human Development. Facts about Down Syndrome, NICHD/NIH website. 2004. www.nichd.nih.gov/publications/pubs/downsyndrome/down.htm.
National Institute of Mental Health. Depression Shares Symptoms with Other Medical Conditions. 1999. www.nimh.nih.gov/depression/senior/shares.htm.
National Organization on Disability. 2004 NOD/Harris Survey on Community Participation. New York, NY. Harris Interactive, Inc. 2004.
National Spinal Cord Injury Statistical Center. Spinal Cord Injury: Facts and Figures at a Glance. Birmingham AL. University of Alabama. 2001. www.spinalcord.uab.edu.
Nosek MA. The John Stanley Coulter lecture. Overcoming the odds: The health of women with physical disabilities in the United States. Archives Physical Medicine and Rehabilitation. 2000;81(2):135-138.
O’Day BL, Killeen M, Iezzoni LI. Improving health care experiences of persons who are blind or have low vision: Suggestions from focus groups. American Journal Medical Quality. 2004;19(5):193-200.
Panko Reis J, Breslin ML, Iezzoni LI, Kirschner KL. It Takes More Than Ramps to Solve the Crisis of Healthcare for People with Disabilities. Chicago IL. Rehabilitation Institute of Chicago. 2004.
Parish SL. Braddock D, editor. Forces shaping developmental disabilities services in the States: A comparative study. Disability at the Dawn of the 21st Century and the State of the States. Washington DC. American Association on Mental Retardation. 2002:353-475.
Pelka F. The ABC-CLIO Companion to the Disability Rights Movement. Santa Barbara CA. ABC-CLIO. 1997.
Pitetti KH, Tan DM. Cardiorespiratory responses of mentally retarded adults to air-brake ergometry and treadmill exercise. Arch Physical Medicine Rehabilitation. 1990;71(5):318-321.
Pope AM, Tarlov AR. Disability in America: Toward A National Agenda For Prevention. Washington DC. National Academy Press. 1991.
Rehabilitation Act of 1973. US Code, vol 29, sec. 701 et seq. 1973.
Rimmer JH, Braddock D, Fujiura G. Prevalence of obesity in adults with mental retardation: Implications for health promotion and disease prevention. Mental Retardation. 1993;31(2):105-110. [pmid: 8479328].
Rimmer JH, Braddock D, Pitetti KH. Research on physical activity and disability: An emerging national priority. Medicine and Science in Sports and Exercise. 1996;28(11):1366-1372. [pmid: 8933486].
Santiago MC, Coyle CP, Kinney WB. Aerobic exercise effect on individuals with physical disabilities. Archives Physical Medicine and Rehabilitation. 1993;74(11):1198-1192.
Shapiro JP. No Pity: People with Disabilities Forging a New Civil Rights Movement. New York NY. Times Books. 1994.
Simeonsson RJ, Leskinen M. Simeonsson RJ, McDevitt, editors. Disability, secondary conditions and quality of life: Conceptual issues. Issues in Disability and Health: The Role of Secondary Conditions and Quality of Life. Chapel Hill NC. University of North Carolina Press. 1999.
Surgeon General of the United States. Closing the Gap: A National Blueprint for Improving the Health of Individuals with Mental Retardation. Report of the Surgeon General’s Conference on Health Disparities and Mental Retardation. Washington DC. Government Printing Office. 2002.
Surgeon General of the United States. Physical Activity and Health: A Report of the Surgeon General. Washington DC. Government Printing Office. 1996.
Thierry JM, Cyril JK. Welner LS, Haseltine F, editors. Health of women with disabilities: From data to action. Welner’s Guide to the Care of Women with Disabilities. Philadelphia PA. Lippincott Williams and Wilkins. 2004:373-382.
Thomas DC. Primary care for people with disabilities. Mount Sinai Journal of Medicine. 1999;66(3):188-191. [pmid: 10377550].
U.S. Census Bureau. Profile of Selected Social Characteristics: 2000, Table DP-2, 2000. www.census.gov/Press-Release/www/2002/dptables/2k00.xls.
U.S. Department of Health and Human Services. Delivering on the Promise: Preliminary Report of Federal Agencies’ Actions to Eliminate Barriers and Promote Community Integration. Washington DC. US Department of Health and Human Services. 2001.
U.S. Department of Health and Human Services. Healthy People 2010: Understanding and Improving Health. 2nd Ed. Washington DC. U.S. Government Printing Office. November. 2000.
U.S. Department of Health and Human Services, New Freedom Commission on Mental Health. Achieving the Promise: Transforming Mental Health Care in America: Final Report. DHHS Pub. No. SMA-03-3832. Rockville MD. Substance Abuse and Mental Health Services Administration. 2003.
U.S. Supreme Court, Olmstead vs. L.C. and E.W. 119 S. Ct. 2176 (1999).
Veltman A, Stewart D, Tardif G, Branigan M. Perceptions of primary healthcare services among people with physical disabilities. Part 1: Access Issues. Medscape Gen Med (serial online). April 6. 2001. www.medscape.com/viewarticle/408122.
Walsh PN, Heller T, Schupf N, van Schrojenstein L, de Valk H. Healthy Aging Adults with Intellectual Disabilities: Women’s Health and Related Issues. Geneva. World Health Organization. 2001.
Welner LS, Haseltine F, editors. Welner’s Guide to the Care of Women with Disabilities. Philadelphia PA. Lippincott Williams and Wilkins. 2004.
Welner SL, Temple B. Welner LS, Haseltine F, editors. General health concerns and the physical examination. Welner’s Guide to the Care of Women with Disabilities. Philadelphia PA. Lippincott Williams and Wilkins. 2004.
Welner SL, Foley CC, Nosek MA, Holmes A. Practical considerations in the performance of physical examinations on women with disabilities. Obstetrical Gynecological Survey. 1999;54(7):457-462. [pmid: 10394583].
West J. The Americans with Disabilities Act: From Policy to Practice. New York NY. Milbank Memorial Fund. 1991.
Wilber N, Mitra M, Walker DK, Allen D, Meyers AR, Tupper P. Disability as a public health issue: Finding and reflections from the Massachusetts survey of secondary conditions. Milbank Quarterly. 2002;80(2):393-421. [pmid: 12101878].
Yamaki K, Rutkowski-Kmitta V, Fujiura GT. Emerging etiology of disablement: State and national policy implications. Institute on Disability and Development. Proceedings of Changing Concepts of Health and Disability: State of the Science Conference and Policy Forum 2003. Portland OR. Oregon Health and Science University. 2003.
Yang Q, Rasmussen SA, Friedman JM. Mortality associated with Down’s syndrome in the USA from 1983 to 1997: A population-based study. Lancet. 2002;59(3):1019-1025. [pmid: 11937181].
Zola IK. Missing Pieces. A Chronicle of Living with a Disability. Philadelphia PA. Temple University Press. 1982.