# Acknowledgments

This Call to Action was prepared by the U.S. Department of Health and Human Services under the direction of the Office of the Surgeon General and the HHS Office on Disability.

- Richard H. Carmona, M.D., M.P.H., FACS
- Surgeon General, United States Public Health
- Service
- Office of the Surgeon General, Office of the
- Secretary
- Washington, D.C.

- Cristina V. Beato, M.D.
- Acting Assistant Secretary for Health
- Office of Public Health and Science, Office of the Secretary
- Washington, D.C.

- Margaret Giannini, M.D., FAAP
- Director
- Office on Disability, Office of the Secretary
- Washington, D.C.

- Kenneth P. Moritsugu, M.D., M.P.H.
- Deputy Surgeon General, United States Public
- Health Service
- Office of the Surgeon General, Office of the
- Secretary
- Washington, D.C.

- Robert C. Williams, P.E., DEE
- Chief of Staff
- Office of the Surgeon General, Office of the
- Secretary
- Washington, D.C.

- Jennifer Cabe, M.A.
- Writer
- Office of the Surgeon General, Office of the
- Secretary
- Washington, D.C.

The editors of the report were

Scientific Editor

- Margaret Giannini, MD, FAAP
- Director
- Office on Disability
- Office of the Secretary
- Washington, DC

Managing Editors

- Edward Brann, MD, MPH
- Director
- Division of Human Development and Disability
- National Center on Birth Defects and Developmental Disabilities
- Centers for Disease Control and Prevention
- Atlanta, GA

- Eileen Elias, MEd
- Deputy Director
- Office on Disability
- Office of the Secretary
- Washington, DC

Scientific Writers

- Theodora Fine, MA, ABD
- Senior Policy and Public Affairs Specialist
- Office on Disability
- Office of the Secretary
- Washington, DC

- JoAnn M. Thierry, PhD, MSW
- Behavioral Scientist
- Disability and Health Team
- Division of Human Development and Disability
- National Center on Birth Defects and Developmental Disabilities
- Centers for Disease Control and Prevention
- Atlanta, GA

Technical Editors

- Jameta Barlow, MPH
- Program Analyst
- Office on Disability
- Office of the Secretary
- Washington, DC

- Connie L. Whitehead
- Senior Writer-Editor
- National Center on Birth Defects and Developmental Disabilities
- Centers for Disease Control and Prevention
- Atlanta, GA

Federal Contributors

- Kari Benson
- Policy Analyst
- Administration on Aging
- Washington, DC

- Linda Bergofsky, MSW, MBA
- Disability, Aging and Long-Term Care Policy
- Office of the Assistant Secretary on Planning and Evaluation
- Washington, DC

- Vincent A. Campbell, PhD
- Associate Director for Science
- Division of Human Development and Disability
- National Center on Birth Defects and Developmental Disabilities
- Centers for Disease Control and Prevention
- Atlanta, VA

- John E. Crews, DPA
- Lead Scientist
- Division of Human Development and Disability
- National Center on Birth Defects and Developmental Disabilities
- Centers for Disease Control and Prevention
- Atlanta, GA

- Robin C. Deykes
- Investigator
- Civil Rights Division
- U.S. Department of Justice
- Washington, DC

- H. Stanley Eichenauer, MSW, ACSW
- Senior Advisor to the Administrator for Mental Health System Transformation
- Substance Abuse and Mental Health Services
- Administration
- Rockville, MD

- Monique Fountain, MD, MPH, MBA
- Director, Medical Home and Healthy Ready to Work Initiatives (HRTW)
- Maternal and Child Health Bureau
- Health Resources and Services Administration
- Rockville, MD

- M. Leonard Genova
- Division of Partnership Development
- Centers for Medicare and Medicaid Services
- Baltimore, MD

- Susan N. Hill, MPA
- Senior Policy Advisor
- Disabled and Elderly Health Programs Group
- Center for Medicaid and State Operations
- Centers for Medicare and Medicaid Services
- Baltimore, MD

- Chris Kochtitzky, MSP
- Deputy Director
- Division of Human Development and Disability
- National Center on Birth Defects and Developmental Disabilities
- Centers for Disease Control and Prevention
- Atlanta, GA

- Diana Lawry, MEd
- Aging Service Program Specialist
- Administration on Aging
- Washington, DC

- Alan Levine
- Senior Program Specialist
- Office of Evaluation and Inspections
- Office of the Inspector General
- Washington, DC

- Marianne Hamilton Lopez, MPA
- Emerging Leaders Program
- National Institutes of Health
- Bethesda, MD

- Saralyn Mark, MD
- Senior Medical Advisor
- Office on Women's Health
- Office of the Secretary
- Washington, DC

- Merle McPherson, MD
- Director, Division of Services for Children with Special Healthcare Needs
- Maternal and Child Health Bureau
- Health Resources and Services Administration
- Rockville, MD

- Jeanne McDowell
- Equal Employment Opportunity Staff
- Center for Devices and Radiological Health
- Food and Drug Administration
- Rockville, MD

- Taya McMillan, MPH
- Service Fellow
- Office of Women’s Health
- Office of the Secretary
- Washington, DC

- Daniel Morales, MPSA
- Acting Director of Communications, Office of Public Health and Science
- Office of the Secretary
- Washington, D.C.

- Ruby Neville, MSW, LGSW
- Public Health Advisor
- Center for Substance Abuse Treatment
- Substance Abuse and Mental Health Services
- Administration
- Rockville, MD

- Allan S. Noonan, MD, MPH
- Scientific Editor
- Office of the Surgeon General, Office of the Secretary
- Washington, D.C.

- Delores Parron, PhD
- Scientific Advisor for Capacity Development
- Office of the Director
- National Institutes of Health
- Bethesda, MD

- Jon Perez, PhD
- Director, Division of Behavioral Health
- Indian Health Service
- Rockville, MD

- Latonya Phipps, Esq
- Emerging Leader
- Office of Equal Opportunity and Diversity
- Management
- National Institutes of Health
- Bethesda, MD

- Louis Quatrano, PhD
- National Center on Medical Rehabilitation
- Research, National Institute of Child Health and Human
- Development
- National Institutes of Health
- Bethesda, MD

- Juliette Rizzo, MJ
- Special Assistant/Senior Public Affairs Specialist
- Office of Internal Communications
- U.S. Department of Education
- Washington, DC

- Margaret Schaefer, MA
- Program Specialist
- Administration on Developmental Disabilities
- Administration for Children and Families
- Washington, DC

- Peggy Schmidt, Med
- Civil Rights Analyst
- Office for Civil Rights
- Office of the Secretary
- Washington, DC

- Curt Shannon, BA
- Writer-Editor
- National Center on Birth Defects and Developmental Disabilities
- Centers for Disease Control and Prevention
- Atlanta, GA

- Craig Stevens, MA
- Director of Communications
- Office of the Surgeon General, Office of the Secretary
- Washington, D.C.

- Bonnie Strickland, PhD
- Chief, Integrated Services for Children with Special Health Needs
- Maternal and Child Health Bureau
- Health Resources and Services Administration
- Rockville, MD

- Charlene Tusan
- Staff Attorney
- Office of the General Counsel
- Office of the Secretary
- Washington, DC

- Janet Valluzzi, MBA, OTR/L
- Service Fellow
- Center for Financing, Access, and Cost Trends
- Agency for Healthcare Research and Quality
- Washington, DC

- Edwin Woo
- Acting Associate General Counsel
- Civil Rights Division
- Office of the General Counsel
- Office of the Secretary
- Washington, DC

Private Sector Contributors

- David B. Gray, PhD
- Associate Professor of Neurology and Associate Professor
- Occupational Therapy Program in Occupational
- Therapy
- Washington University School of Medicine
- St. Louis, MO

- Nancy Lee Head
- Mental Health Consumer, Retired Program
- Director
- National Alliance for the Mentally Ill, District of Columbia Chapter
- Arlington, VA

- Lisa Iezzoni, MD, MSc
- Professor of Medicine, Harvard Medical School
- Division of General Medicine and Primary Care
- Beth Israel Deaconess Medical Center
- Boston, MA

- John D. Kemp, JD
- Powers, Pyles, Sutter & Verville, L.C.
- Washington, DC
- Maggie Nygren
- Technical Assistance Director
- Association of University Centers on Disability
- Silver Spring, MD

- Marcie Roth
- Parent of children with disabilities
- Executive Director, National Spinal Cord Injury
- Association
- Bethesda, MD

- Clifford Thorne
- Chairperson
- District of Columbia State Rehabilitation
- Council
- Washington, DC

- Steven Towle
- Washington Liaison
- National Association of Alcohol, Drugs and Disability
- Rockville, MD