# Acknowledgments

This Call to Action was prepared by the U.S. Department of Health and Human Services (HHS) under the direction of the Office of the Surgeon General and the National Heart, Lung, and Blood Institute (NHLBI) of the National Institutes of Health.

Rear Admiral Steven K. Galson, M.D., M.P.H.; Acting Surgeon General, United States Public Health Service; Office of the Surgeon General; Office of Public Health and Science; Office of the Secretary; United States Department of Health and Human Services; Washington, DC.

Rear Admiral Robert C. Williams, P.E., DEE; Acting Deputy Surgeon General, United States Public Health Service; Office of the Surgeon General; Office of Public Health and Science; Office of the Secretary; United States Department of Health and Human Services; Washington, DC.

Rear Admiral Carol A. Romano, Ph.D., R.N., FAAN; Acting Chief of Staff, United States Public Health Service; Office of the Surgeon General; Office of Public Health and Science; Office of the Secretary; United States Department of Health and Human Services; Washington, DC.

Elizabeth G. Nabel, M.D.; Director, National Heart, Lung, and Blood Institute; National Institutes of Health; United States Department of Health and Human Services; Bethesda, MD.

Mary Beth Bigley, Dr.P.H., M.S.N., A.N.P.; Acting Director, Office of Science and Communications Office of the Surgeon General Office; United States Department of Health and Human Services; Washington, DC.

Richard H. Carmona, M.D., M.P.H., F.A.C.S.; Former Surgeon General; Office of the Surgeon General; Office of Public Health and Science; Office of the Secretary; United States Department of Health and Human Services; Washington, DC.

Pankaj Ganguly, Ph.D.; Former Program Director, Thrombosis and Hemostasis Program; Division of Blood Diseases and Resources; National Heart, Lung, and Blood Institute; National Institutes of Health; United States Department of Health and Human Services; Bethesda, MD.

Ahmed A. K. Hasan, M.D., Ph.D.; Program Administrator, Thrombosis and Hemostasis Program; Division of Blood Diseases and Resources; National Heart, Lung, and Blood Institute; National Institutes of Health; United States Department of Health and Human Services; Bethesda, MD.

Keith L. Hewitt; Contract Conference Coordinator, Division for the Application of Research Discoveries; National Heart, Lung, and Blood Institute; National Institutes of Health; United States Department of Health and Human Services; Bethesda, MD.

Rebecca Link, Ph.D.; Scientific Research Group Leader, Thrombosis and Hemostasis Program; Division of Blood Diseases and Resources; National Heart, Lung, and Blood Institute; National Institutes of Health; United States Department of Health and Human Services; Bethesda, MD.

Gregory J. Morosco, Ph.D., M.P.H.; Director, Division for the Application of Research Discoveries; National Heart, Lung, and Blood Institute; National Institutes of Health; United States Department of Health and Human Services; Bethesda, MD.

Rear Admiral (Retired) Kenneth P. Moritsugu, M.D., M.P.H.; Former Acting Surgeon General, United States Public Health Service; Office of the Surgeon General; Office of Public Health and Science; Office of the Secretary; United States Department of Health and Human Services; Washington, DC.

Karen A. Near, M.D., M.S.; Former Senior Science Advisor; Office of the Surgeon General; Office of Public Health and Science; Office of the Secretary; United States Department of Health and Human Services; Washington, DC.

Lieutenant Joel A. Nelson, M.S.W., M.P.H.; Special Assistant, United States Public Health Service; Office of the Surgeon General; Office of Public Health and Science; Office of the Secretary; United States Department of Health and Human Services; Washington, DC.

Charles M. Peterson, M.D., M.B.A.; Former Director, Division of Blood Diseases and Resources; National Heart, Lung, and Blood Institute; National Institutes of Health; United States Department of Health and Human Services; Bethesda, MD.

Nancy J. Poole, M.B.A.; Senior Manager for Program Operations, Division for the Application of Research Discoveries; National Heart, Lung, and Blood Institute; National Institutes of Health; United States Department of Health and Human Services; Bethesda, MD.

Peter D. Rumm, M.D., M.P.H.; Deputy Director, General Surgical Branch, Plastic and Reconstructive Surgery Branch, and Restorative Branch; Division of General, Restorative, and Neurological Devices; Office of Device Evaluation; Center for Devices and Radiological Health; Food and Drug Administration; United States Department of Health and Human Services; Washington, DC.

Lieutenant Junior Grade Rebekah A. Sagan, M. P. H.; Special Assistant, United States Public Health Service; Office of the Surgeon General; Office of Public Health and Science; Office of the Secretary; United States Department of Health and Human Services; Washington, DC.

Ron Schoenfeld, Ph.D.; Former Senior Science Advisor; Office of the Surgeon General; Office of Public Health and Science; Office of the Secretary; United States Department of Health and Human Services; Washington, DC.

Susan T. Shero, R.N., M.S.; Public Health Advisor, Division for the Application of Research Discoveries; National Heart, Lung, and Blood Institute; National Institutes of Health; United States Department of Health and Human Services; Bethesda, MD.

Lieutenant Junior Grade Jeffery R. Strich, M.S.; Special Assistant, United States Public Health Service; Office of the Surgeon General; Office of Public Health and Science; Office of the Secretary; United States Department of Health and Human Services; Washington, DC.

Mary L. Westcott, Ph.D.; Contract Writer-Editor, Division for the Application of Research Discoveries; National Heart, Lung, and Blood Institute; National Institutes of Health; United States Department of Health and Human Services; Bethesda, MD.

Terri L. Williams, M.S.A.; Production Manager, Division for the Application of Research Discoveries; National Heart, Lung, and Blood Institute; National Institutes of Health; United States Department of Health and Human Services; Bethesda, MD.

Editors of The Call To Action:

Samuel Z. Goldhaber, M.D.; Professor of Medicine, Brigham and Women’s Hospital; Boston, MA.

Thomas L. Ortel, M.D., Ph.D.; Professor of Medicine, Hemostasis and Thrombosis Center; Duke University Medical Center; Durham, NC.

Science Writer:

Larry S. Stepnick, M.B.A.; The Severyn Group, Inc.; Ashburn, VA.