# References

1 Piazza G, Goldhaber SZ. Acute pulmonary embolism: part I: epidemiology and diagnosis. Circulation. 2006;114(2):e28-32. [pmid: 16831989].
2 Piazza G, Goldhaber SZ. Acute pulmonary embolism: part II: treatment and prophylaxis. Circulation. 2006;114(3):e42-7. [pmid: 16847156].
3 Mohr DN, Silverstein MD, Heit JA, Petterson TM, O’Fallon WM, Melton LJ. The venous stasis syndrome after deep venous thrombosis or pulmonary embolism: a population-based study. Mayo Clin Proc. 2000;75(12):1249-56. [pmid: 11126832].
4 Prandoni P, Lensing AW, Cogo A, Cuppini S, Villalta S, Carta M, et al. The long-term clinical course of acute deep venous thrombosis. Ann Intern Med. 1996;125(1):1-7. [pmid: 8644983].
5 Heit JA, Mohr DN, Silverstein MD, Petterson TM, O’Fallon WM, Melton LJ 3rd. Predictors of recurrence after deep vein thrombosis and pulmonary embolism: a population-based cohort study. Arch Intern Med. 2000;160(6):761-8. [pmid: 10737275].
6 Heit JA, Silverstein MD, Mohr DN, Petterson TM, O’Fallon WM, Melton LJ 3rd. Predictors of survival after deep vein thrombosis and pulmonary embolism: a population-based, cohort study. Arch Intern Med. 1999;159(5):445-53. [pmid: 10074952].
7 Kearon C. Natural history of venous thromboembolism. Circulation. 2003;107(23 Suppl 1):I22-30. [pmid: 12814982].
8 Silverstein MD, Heit JA, Mohr DN, Petterson TM, O’Fallon WM, Melton LJ 3rd. Trends in the incidence of deep vein thrombosis and pulmonary embolism: a 25-year population-based study. Arch Intern Med. 1998;158(6):585-93. [pmid: 9521222].
9 US Census Bureau News. Nation’s Population to reach 300 Million on Oct 17. U.S. Department of Commerce Public Information Office. October 12. 2006. Available at: http://www.census.gov/Press-Release/www/releases/archives/population/007616.html. 2006.
10 Anderson FA Jr, Wheeler HB, Goldberg RJ, Hosmer DW, Patwardhan NA, Jovanovic B, et al. A population-based perspective of the hospital incidence and case-fatality rates of deep vein thrombosis and pulmonary embolism. The Worcester DVT Study. Arch Intern Med. 1991;151(5):933-8. [pmid: 2025141].
11 Gross JS, Neufeld RR, Libow LS, Gerber I, Rodstein M. Autopsy study of the elderly institutionalized patient. Review of 234 autopsies. Arch Intern Med. 1988;148(1):173-6. [pmid: 3337592].
12 Rossman I, Rodstein M, Bornstein A. Undiagnosed diseases in an aging population. Pulmonary embolism and bronchopneumonia. Arch Intern Med. 1974;133(3):366-9. [pmid: 4283736].
13 Heit JA. Venous thromboembolism: disease burden, outcomes and risk factors. J Thromb Haemost. 2005;3(8):1611-7. [pmid: 16102026].
14 Stein PD, Beemath A, Olson RE. Trends in the incidence of pulmonary embolism and deep venous thrombosis in hospitalized patients. Am J Cardiol. 2005;95(12):1525-6. [pmid: 15950590].
15 AHA. American Heart Association. Venous Thromboembolism - Statistics. Statistical Fact Sheet, 2004. Available at: http://www.americanheart.org/downloadable/heart/1136823273598VenousThromb06.pdf. 2004.
16 Horlander KT, Mannino DM, Leeper KV. Pulmonary embolism mortality in the United States, 1979–1998: an analysis using multiple-cause mortality data. Arch Intern Med. 2003;163(14):1711-7. [pmid: 12885687].
17 Heit JA, Silverstein MD, Mohr DN, Petterson TM, Lohse CM, O’Fallon WM, et al. The epidemiology of venous thromboembolism in the community. Thromb Haemost. 2001;86(1):452-63. [pmid: 11487036].
18 Heit JA. The epidemiology of venous thromboembolism in the community: implications for prevention and management. J Thromb Thrombolysis. 2006;21(1):23-9. [pmid: 16475038].
19 Prandoni P, Bernardi E, Marchiori A, Lensing AW, Prins MH, Villalta S, et al. The long term clinical course of acute deep vein thrombosis of the arm: prospective cohort study. Bmj. 2004;329(7464):484-5. [pmid: 15256419].
20 Schulman S, Lindmarker P, Holmstrom M, Larfars G, Carlsson A, Nicol P, et al. Post-thrombotic syndrome, recurrence, and death 10 years after the first episode of venous thromboembolism treated with warfarin for 6 weeks or 6 months. J Thromb Haemost. 2006;4(4):734-42. [pmid: 16634738].
21 Eichinger S, Weltermann A, Minar E, Stain M, Schonauer V, Schneider B, et al. Symptomatic pulmonary embolism and the risk of recurrent venous thromboembolism. Arch Intern Med. 2004;164(1):92-6. [pmid: 14718328].
22 Kyrle PA, Minar E, Bialonczyk C, Hirschl M, Weltermann A, Eichinger S. The risk of recurrent venous thromboembolism in men and women. N Engl J Med. 2004;350(25):2558-63. [pmid: 15201412].
23 Kahn SR, Kearon C, Julian JA, Mackinnon B, Kovacs MJ, Wells P, et al. Predictors of the post-thrombotic syndrome during long-term treatment of proximal deep vein thrombosis. J Thromb Haemost. 2005;3(4):718-23. [pmid: 15733061].
24 Kahn SR, M’Lan CE, Lamping DL, Kurz X, Berard A, Abenhaim L. The influence of venous thromboembolism on quality of life and severity of chronic venous disease. J Thromb Haemost. 2004;2(12):2146-51. [pmid: 15613019].
25 Kahn SR, Ducruet T, Lamping DL, Arsenault L, Miron MJ, Roussin A, et al. Prospective evaluation of health-related quality of life in patients with deep venous thrombosis. Arch Intern Med. 2005;165(10):1173-8. [pmid: 15911732].
26 White RH, Zhou H, Murin S, Harvey D. Effect of ethnicity and gender on the incidence of venous thromboembolism in a diverse population in California in 1996. Thromb Haemost. 2005;93(2):298-305. [pmid: 15711746].
27 White RH, Zhou H, Romano PS. Incidence of idiopathic deep venous thrombosis and secondary thromboembolism among ethnic groups in California. Ann Intern Med. 1998;128(9):737-40. [pmid: 9556467].
28 Prandoni P. Acquired risk factors for venous thromboembolism in medical patients. Hematology Am Soc Hematol Educ Program. 2005:458-61.
29 Rosendaal FR. Venous thrombosis: the role of genes, environment, and behavior. Hematology Am Soc Hematol Educ Program. 2005:1-12.
30 Cushman M. Inherited risk factors for venous thrombosis. Hematology Am Soc Hematol Educ Program. 2005:452-7.
31 Vossen CY, Conard J, Fontcuberta J, Makris M, FJ VDM, Pabinger I, et al. Risk of a first venous thrombotic event in carriers of a familial thrombophilic defect. The European Prospective Cohort on Thrombophilia (EPCOT). J Thromb Haemost. 2005;3(3):459-64. [pmid: 15748234].
32 Rees DC, Cox M, Clegg JB. World distribution of factor V Leiden. Lancet. 1995;346(8983):1133-4. [pmid: 7475606].
33 Rosendaal FR, Doggen CJ, Zivelin A, Arruda VR, Aiach M, Siscovick DS, et al. Geographic distribution of the 20210 G to A prothrombin variant. Thromb Haemost. 1998;79(4):706-8. [pmid: 9569177].
34 Poort SR, Rosendaal FR, Reitsma PH, Bertina RM. A common genetic variation in the 3’-untranslated region of the prothrombin gene is associated with elevated plasma prothrombin levels and an increase in venous thrombosis. Blood. 1996;88(10):3698-703. [pmid: 8916933].
35 Tait RC, Walker ID, Reitsma PH, Islam SI, McCall F, Poort SR, et al. Prevalence of protein C deficiency in the healthy population. Thromb Haemost. 1995;73(1):87-93. [pmid: 7740502].
36 Tait RC, Walker ID, Perry DJ, Islam SI, Daly ME, McCall F, et al. Prevalence of antithrombin deficiency in the healthy population. Br J Haematol. 1994;87(1):106-12. [pmid: 7947234].
37 Demers C, Ginsberg JS, Hirsh J, Henderson P, Blajchman MA. Thrombosis in antithrombin-III-deficient persons. Report of a large kindred and literature review. Ann Intern Med. 1992;116(9):754-61. [pmid: 1489375].
38 Hoffman R, Brenner B. Thrombophilia related issues in women and children. Semin Thromb Hemost. 2005;31(1):97-103. [pmid: 15706481].
39 Poulter NR, Chang CL, Marmot M, Farley TM, Meirik O. Third-generation oral contraceptives and venous thrombosis. Lancet. 1997;349(9053):732. [pmid: 9078227].
40 Jick H, Jick SS, Gurewich V, Myers MW, Vasilakis C. Risk of idiopathic cardiovascular death and nonfatal venous thromboembolism in women using oral contraceptives with differing progestagen components. Lancet. 1995;346(8990):1589-93. [pmid: 7500750].
41 Farmer RD, Lawrenson RA, Thompson CR, Kennedy JG, Hambleton IR. Population-based study of risk of venous thromboembolism associated with various oral contraceptives. Lancet. 1997;349(9045):83-8. [pmid: 8996419].
42 Wu O, Robertson L, Langhorne P, Twaddle S, Lowe GD, Clark P, et al. Oral contraceptives, hormone replacement therapy, thrombophilias and risk of venous thromboembolism: a systematic review. The Thrombosis: Risk and Economic Assessment of Thrombophilia Screening (TREATS) Study. Thromb Haemost. 2005;94(1):17-25. [pmid: 16113779].
43 Romero A, Alonso C, Rincon M, Medrano J, Santos JM, Calderon E, et al. Risk of venous thromboembolic disease in women A qualitative systematic review. Eur J Obstet Gynecol Reprod Biol. 2005;121(1):8-17. [pmid: 15950363].
44 FDA. Ortho Evra (norelgestromin/ethinyl estradiol transdermal system). United States Food and Drug Administration. MedWatch. Nov. 10. 2005:P05-90.
45 Heinemann LA, Assmann A, DoMinh T, Garbe E. Oral progestogen-only contraceptives and cardiovascular risk: results from the Transnational Study on Oral Contraceptives and the Health of Young Women. Eur J Contracept Reprod Health Care. 1999;4(2):67-73. [pmid: 10427481].
46 Lidegaard O, Edstrom B, Kreiner S. Oral contraceptives and venous thromboembolism: a five-year national case-control study. Contraception. 2002;65(3):187-96. [pmid: 11929640].
47 WHO. Cardiovascular disease and use of oral and injectable progestogen-only contraceptives and combined injectable contraceptives. Results of an international, multicenter, case-control study. World Health Organization Collaborative Study of Cardiovascular Disease and Steroid Hormone Contraception. Contraception. 1998;57(5):315-324. [pmid: 9673838].
48 De Stefano V, Rossi E, Leone G. Inherited thrombophilia, pregnancy, and oral contraceptive use: clinical implications. Semin Vasc Med. 2003;3(1):47-60. [pmid: 15199492].
49 Mac Gillavry MR, Prins M. Oral contraceptives and inherited thrombophilia: a gene-environment interaction with a risk of venous thrombosis?. Semin Thromb Hemost. 2003;29(2):219-26. [pmid: 12709926].
50 Heit JA, Kobbervig CE, James AH, Petterson TM, Bailey KR, Melton LJ 3rd. Trends in the incidence of venous thromboembolism during pregnancy or postpartum: a 30-year population-based study. Ann Intern Med. 2005;143(10):697-706. [pmid: 16287790].
51 Berg CJ, Atrash HK, Koonin LM, Tucker M. Pregnancy-related mortality in the United States, 1987–1990. Obstet Gynecol. 1996;88(2):161-7. [pmid: 8692494].
52 Grady D, Wenger NK, Herrington D, Khan S, Furberg C, Hunninghake D, et al. Postmenopausal hormone therapy increases risk for venous thromboembolic disease. The Heart and Estrogen/progestin Replacement Study. Ann Intern Med. 2000;132(9):689-96. [pmid: 10787361].
53 Rossouw JE, Anderson GL, Prentice RL, LaCroix AZ, Kooperberg C, Stefanick ML, et al. Risks and benefits of estrogen plus progestin in healthy postmenopausal women: principal results From the Women’s Health Initiative randomized controlled trial. Jama. 2002;288(3):321-33. [pmid: 12117397].
54 Perez Gutthan S, Garcia Rodriguez LA, Castellsague J, Duque Oliart A. Hormone replacement therapy and risk of venous thromboembolism: population based case-control study. BMJ. 1997;314(7083):796-800. [pmid: 9081000].
55 Jick H, Derby LE, Myers MW, Vasilakis C, Newton KM. Risk of hospital admission for idiopathic venous thromboembolism among users of postmenopausal oestrogens. Lancet. 1996;348(9033):981-3. [pmid: 8855853].
56 Prandoni P, Lensing AW, Buller HR, Cogo A, Prins MH, Cattelan AM, et al. Deep-vein thrombosis and the incidence of subsequent symptomatic cancer. N Engl J Med. 1992;327(16):1128-33. [pmid: 1528208].
57 Blom JW, Vanderschoot JP, Oostindier MJ, Osanto S, van der Meer FJ, Rosendaal FR. Incidence of venous thrombosis in a large cohort of 66,329 cancer patients: results of a record linkage study. J Thromb Haemost. 2006;4(3):529-35. [pmid: 16460435].
58 Chew HK, Wun T, Harvey D, Zhou H, White RH. Incidence of venous thromboembolism and its effect on survival among patients with common cancers. Arch Intern Med. 2006;166(4):458-64. [pmid: 16505267].
59 Stein PD, Beemath A, Meyers FA, Skaf E, Sanchez J, Olson RE. Incidence of venous thromboembolism in patients hospitalized with cancer. Am J Med. 2006;119(1):60-8. [pmid: 16431186].
60 Zangari M, Anaissie E, Barlogie B, Badros A, Desikan R, Gopal AV, et al. Increased risk of deep-vein thrombosis in patients with multiple myeloma receiving thalidomide and chemotherapy. Blood. 2001;98(5):1614-5. [pmid: 11520815].
61 Heit JA, Silverstein MD, Mohr DN, Petterson TM, O’Fallon WM, Melton LJ 3rd. Risk factors for deep vein thrombosis and pulmonary embolism: a population-based case-control study. Arch Intern Med. 2000;160(6):809-15. [pmid: 10737280].
62 Kucuk O, Kwaan HC, Gunnar W, Vazquez RM. Thromboembolic complications associated with L-asparaginase therapy. Etiologic role of low antithrombin III and plasminogen levels and therapeutic correction by fresh frozen plasma. Cancer. 1985;55(4):702-6. [pmid: 3855365].
63 Kuenen BC, Rosen L, Smit EF, Parson MR, Levi M, Ruijter R, et al. Dose-finding and pharmacokinetic study of cisplatin, gemcitabine, and SU5416 in patients with solid tumors. J Clin Oncol. 2002;20(6):1657-67. [pmid: 11896117].
64 Pritchard KI, Paterson AH, Paul NA, Zee B, Fine S, Pater J. Increased thromboembolic complications with concurrent tamoxifen and chemotherapy in a randomized trial of adjuvant therapy for women with breast cancer. National Cancer Institute of Canada Clinical Trials Group Breast Cancer Site Group. J Clin Oncol. 1996;14(10):2731-7. [pmid: 8874334].
65 Wun T, Law L, Harvey D, Sieracki B, Scudder SA, Ryu JK. Increased incidence of symptomatic venous thrombosis in patients with cervical carcinoma treated with concurrent chemotherapy, radiation, and erythropoietin. Cancer. 2003;98(7):1514-20. [pmid: 14508840].
66 Levitan N, Dowlati A, Remick SC, Tahsildar HI, Sivinski LD, Beyth R, et al. Rates of initial and recurrent thromboembolic disease among patients with malignancy versus those without malignancy. Risk analysis using Medicare claims data. Medicine (Baltimore). 1999;78(5):285-91. [pmid: 10499070].
67 White RH, Chew HK, Zhou H, Parikh-Patel A, Harris D, Harvey D, et al. Incidence of venous thromboembolism in the year before the diagnosis of cancer in 528,693 adults. Arch Intern Med. 2005;165(15):1782-7. [pmid: 16087828].
68 Geerts WH, Pineo GF, Heit JA, Bergqvist D, Lassen MR, Colwell CW, et al. Prevention of venous thromboembolism: the Seventh ACCP Conference on Antithrombotic and Thrombolytic Therapy. Chest. 2004;126(3 Suppl):338S-400S. [pmid: 15383478].
69 Tsai AW, Cushman M, Rosamond WD, Heckbert SR, Polak JF, Folsom AR. Cardiovascular risk factors and venous thromboembolism incidence: the longitudinal investigation of thromboembolism etiology. Arch Intern Med. 2002;162(10):1182-9. [pmid: 12020191].
70 Samama MM. An epidemiologic study of risk factors for deep vein thrombosis in medical outpatients: the Sirius study. Arch Intern Med. 2000;160(22):3415-20. [pmid: 11112234].
71 Abdollahi M, Cushman M, Rosendaal FR. Obesity: risk of venous thrombosis and the interaction with coagulation factor levels and oral contraceptive use. Thromb Haemost. 2003;89(3):493-498. [pmid: 12624633].
72 Baglin TP, White K, Charles A. Fatal pulmonary embolism in hospitalised medical patients. J Clin Pathol. 1997;50(7):609-10. [pmid: 9306945].
73 Alikhan R, Cohen AT, Combe S, Samama MM, Desjardins L, Eldor A, et al. Risk factors for venous thromboembolism in hospitalized patients with acute medical illness: analysis of the MEDENOX Study. Arch Intern Med. 2004;164(9):963-8. [pmid: 15136304].
74 Goldhaber SZ, Turpie AG. Prevention of venous thromboembolism among hospitalized medical patients. Circulation. 2005;111(1):e1-3. [pmid: 15630031].
75 Heit JA, O’Fallon WM, Petterson TM, Lohse CM, Silverstein MD, Mohr DN, et al. Relative impact of risk factors for deep vein thrombosis and pulmonary embolism: a population-based study. Arch Intern Med. 2002;162(11):1245-8. [pmid: 12038942].
76 Cannegieter SC, Doggen CJ, van Houwelingen HC, Rosendaal FR. Travel-related venous thrombosis: results from a large population-based case control study (MEGA study). PLoS Med. 2006;3(8):e307. [pmid: 16933962].
77 Steffen LM, Folsom AR, Cushman M, Jacobs DR Jr, Rosamond WD. Greater fish, fruit, and vegetable intakes are related to lower incidence of venous thromboembolism: the Longitudinal Investigation of Thromboembolism Etiology. Circulation. 2007;115(2):188-95. [pmid: 17179018].
78 Kohn LT, Corrigan JM, Donaldson M. To Err Is Human: Building a Safer Health System. Washington, D.C. Institute of Medicine. 1999.
79 Shojania KG, Duncan BW, McDonald KM, Wachter RM, Markowitz AJ. Making health care safer: a critical analysis of patient safety practices. Evid Rep Technol Assess (Summ). 2001;(43):i-x. 1. 668.
80 AHRQ. Safe Practices for Better Healthcare: A Consensus Report Summary The National Quality Forum. Agency for Healthcare Research and Quality. Rockville, MD. Available at: http://www.ahrq.gov/qual/nqfpract.htm. 2003.
81 NQF. National Quality Forum Endorses Consensus Standards For Prevention and Care of Venous Thromboembolism. 2006. May 18. Press Release. Available at: http://216.122.138.39/pdf/news/DVT5-18-06.pdf. 2006.
82 Goldhaber SZ, Tapson VF. A prospective registry of 5,451 patients with ultrasound-confirmed deep vein thrombosis. Am J Cardiol. 2004;93(2):259-62. [pmid: 14715365].
83 Kucher N, Tapson VF, Quiroz R, Mir SS, Morrison RB, McKenzie D, et al. Gender differences in the administration of prophylaxis to prevent deep venous thrombosis. Thromb Haemost. 2005;93(2):284-8. [pmid: 15711744].
84 Anderson FA Jr, Wheeler HB, Goldberg RJ, Hosmer DW, Forcier A, Patwardhan NA. Physician practices in the prevention of venous thromboembolism. Ann Intern Med. 1991;115(8):591-5. [pmid: 1892330].
85 Steier KJ, Singh G, Ullah A, Maneja J, Ha RS, Khan F. Venous thromboembolism: application and effectiveness of the American College of Chest Physicians 2001 guidelines for prophylaxis. J Am Osteopath Assoc. 2006;106(7):388-95. [pmid: 16912336].
86 Rahim SA, Panju A, Pai M, Ginsberg J. Venous thromboembolism prophylaxis in medical inpatients: a retrospective chart review. Thromb Res. 2003;111(4–5):215-9. [pmid: 14693166].
87 Stratton MA, Anderson FA, Bussey HI, Caprini J, Comerota A, Haines ST, et al. Prevention of venous thromboembolism: adherence to the 1995 American College of Chest Physicians consensus guidelines for surgical patients. Arch Intern Med. 2000;160(3):334-40. [pmid: 10668835].
88 Tapson VF, Hyers TM, Waldo AL, Ballard DJ, Becker RC, Caprini JA, et al. Antithrombotic therapy practices in US hospitals in an era of practice guidelines. Arch Intern Med. 2005;165(13):1458-64. [pmid: 16009860].
89 Caprini JA, Tapson VF, Hyers TM, Waldo AL, Wittkowsky AK, Friedman R, et al. Treatment of venous thromboembolism: adherence to guidelines and impact of physician knowledge, attitudes, and beliefs. J Vasc Surg. 2005;42(4):726-33. [pmid: 16242561].
90 NICS. National Institute of Clinical Studies (NICS). Interventions to Improve Uptake of Venous Thromboembolism Prophlaxis in Hospitals. 2003. Prepared by Australian Safety and Efficacy Register of New Interventional Procedures - Surgical (ASERNIP-S). NICS, Melbourne. Available at: http://www.nicsl.com.au/asp/index.asp. 2003.
91 NICS. National Institute of Clinical Studies. Interventions to Improve Uptake of Venous Thromboembolism Prophlaxis in Hospitals. Prepared by Australian Safety and Efficacy Register of New Interventional Procedures - Surgical (ASERNIP-S). NICS, Melbourne. Avialble at: http://www.nicsl.com.au/asp/index.asp. 2003.
92 Kucher N, Koo S, Quiroz R, Cooper JM, Paterno MD, Soukonnikov B, et al. Electronic alerts to prevent venous thromboembolism among hospitalized patients. N Engl J Med. 2005;352(10):969-77. [pmid: 15758007].
93 APHA. American Public Health Association. Deep-Vein Thrombosis: Advancing Awareness to Protect Patient Lives. Public Health Leadership Conference on Deep-Vein Thrombosis. White Paper. Public Health Leadership Conference on Deep-Vein Thrombosis. February 26, 2003. 2003.
94 DHHS. Deep Vein Thrombosis Workshop Proceedings. US Department of Health and Human Services. Office of the Surgeon General. Available at: http://www.surgeongeneral.gov/topics/deepvein/. 2006.
95 Varga EA, Moll S. Education needs of patients and families with thrombosis and thrombophilia: results from two patient education seminars. Proceedings of the Eighth National Conference on Anticoagulant Therapy. Orlando, FL, May 5th 2005. J Thromb Thrombolysis. 2006;21(1):107.
96 Varga EA, Moll S. Availability of educational materials for patients and families with thrombosis and thrombophilia-a review of printed and web-based literature. Proceedings of the Eighth National Conference on Anticoagulant Therapy. Orlando, FL, May 5th 2005. J Thromb Thrombolysis. 2006;21(1):107.
97 Dowling NF, Beckman MG, Manco-Johnson M, Hassell K, Philipp CS, Michaels LA, et al. The U.S. Thrombosis and Hemostasis Centers pilot sites program. J Thromb Thrombolysis. 2007;23(1):1-7. [pmid: 17111206].