# Message from the Director of the National, Heart, Lung, and Blood Institute, National Institutes of Health

Thousands of Americans suffer from deep vein thrombosis (DVT) in the United States today, and many will die from its complication, pulmonary embolism (PE). The tragedy of these diseases is that their diagnosis is easy to overlook because the signs and symptoms are often diffuse and difficult to recognize. In many cases, there are no clinically apparent signs at all. Perhaps as many as 50 percent of the cases of DVT are “silent.” Very often the first symptom of DVT is a fatal PE.

There are few public health problems as serious as DVT/PE, yet these diseases receive so little attention. Some estimates suggest that these conditions cause more deaths each year than breast cancer, AIDS, or motor vehicle incidents—illnesses or injuries that are well understood by most Americans. Up until now, levels of public awareness and knowledge about the risks of these diseases have been extremely low. The “Surgeon General’s Call to Action to Prevent Deep Vein Thrombosis and Pulmonary Embolism” finds the status quo unacceptable.

The National Heart, Lung, and Blood Institute (NHLBI) is the primary agency within the National Institutes of Health that is responsible for promoting research leading to improved diagnosis and treatment of DVT/PE. The NHLBI has a long and distinguished record of supporting and guiding seminal advances in thrombosis research that have yielded unprecedented improvements in the nation’s health. It has supported basic research in venous biology for the development of improved treatment for venous diseases and their complications; indeed, much of the science contained in this Call to Action is a result of NHLBI-funded research. Despite these accomplishments, there are many factors that impede progress in research and treatment, including a limited understanding of venous biology and coagulation proteins, and the lack of a critical mass of investigators and providers devoted to this research. Without technological innovation, training opportunities, and committed investigators, progress will continue to be slow.

It is NHLBI’s hope that this Call to Action will stimulate innovative research by investigators who are committed to finding new ways to prevent and treat these conditions. As the Surgeon General stated at his workshop on DVT in May of 2006, there are many differences in how health professionals deal with the issue, and there is no consensus nationally by practitioners and hospitals on the best way to approach this problem. There is also an urgent need to develop a consensus on science-based standards of care, especially for high-risk groups. It is critical that we identify new areas of research related to venous biology, DVT/ PE, their complications, and clinical interventions. This kind of basic and clinical science is needed to provide a foundation for the development of evidence-based guidelines.

This Call to Action concludes that in order to impact the incidence and burden of DVT/PE, stakeholders need to come together to increase public awareness, support the development of evidence-based practices, and carry out the scientific research that can address the gaps in knowledge. I urge all of us to work together to achieve this ambitious and essential vision. This is a vision that the NHLBI wholeheartedly supports.