# CONCLUSION: A Vision for the Future

As the previous section illustrates, there is no shortage of interest in grappling with the problem of DVT/PE. High-profile individuals and organizations with substantial resources are committed to the task. The key for these stakeholders is to come together to build a coordinated plan that can lead to a dramatic reduction in the incidence and burden of these diseases in this nation.

This Call to Action is for all who can have an impact on the incidence and burden of DVT and PE in the United States. It calls for these stakeholders to take effective action to create a future where:

- The public at large is knowledgeable about the risk factors, triggering events, and symptoms of these diseases, and individuals feel empowered to talk with their clinicians about them whenever appropriate.
- Evidence-based practices for the screening, prevention, diagnosis, and treatment of DVT/ PE are clearly understood and routinely applied by all medical professionals in all settings.
- New scientific evidence is routinely being discovered to fill gaps in knowledge, and these findings are quickly and easily disseminated to the public and put into practice by health professionals.

The overall results of this action agenda will be to save tens of thousands of lives each year and to reduce the suffering for many more. Implementing this vision will not be an easy task, and progress will take time. Many barriers stand in the way, but solutions must be found and, more importantly, set into motion. We will need the energy and commitment of individuals, families, the health care system, private sector organizations, and government at all levels to work together to build solutions that will bring better health to Americans. With these dedicated efforts we can make this vision a reality.