# SECTION V: A Catalyst for Action

This “Surgeon General’s Call to Action to Prevent Deep Vein Thrombosis and Pulmonary Embolism” is intended to serve as a catalyst for the development of coordinated efforts to prevent and treat these diseases. Translating the ideas raised in this report will require a great national commitment. Collectively identifying current gaps in knowledge and action, and developing and initiating programs to fill those gaps are necessary. Public and private partnerships will be critical to this task. While the magnitude of the problem is great, the range of potential solutions is even greater. The design of successful interventions and actions for prevention and appropriate diagnosis and treatment of DVT/PE will require the careful attention of many individuals and organizations working together at multiple levels.

## The Power of Partnerships

Partnerships and collaborations can be powerful vehicles for stimulating positive change. These collaborations can play a critical role in any or all of the following:

- educating the public, patients, and healthcare providers
- assessing the true educational needs and evaluating educational efforts through formal research
- creating and distributing educational messages and materials for the public and patients through seminars, printed material, Web sites, and the media
- educating various health care provider groups
- encouraging the development of scientific studies for at-risk populations
- promoting the development of evidence-based standards related to prevention, diagnosis, and treatment
- making existing standards accessible and easy to use for all providers
- participating in the development of national treatment guidelines and endorsing them.

Fortunately, there are already successful partnerships on which to build. A number of them are included in the presentations given at the Surgeon General’s Workshop on Deep Vein Thrombosis (www.surgeongeneral.gov/topics/deepvein/). The following are three examples.

### Government-Provider Collaboration

The Thrombosis and Hemostasis Centers Pilot Program was initiated in 2001 as a collaborative program between the Division of Blood Disorders of the Centers for Disease Control and Prevention and eight Thrombosis and Hemostasis Centers. The intended purpose of the program is to:

- determine the efficacy of integrated multi-disciplinary care and prevention services for persons with hemostatic disorders to reduce morbidity and mortality associated with bleeding and clotting diseases
- assess unmet needs for service delivery and identify outreach strategies designed to improve access to care
- develop effective messages aimed at disease management and prevention; and
- foster the development of training programs to enhance provider skills for the delivery of hemostasis and thrombosis care.

During the first five years of this pilot program, the collaborative program has established a patient registry that includes over 3,300 patients (as of October 2006) and has published a manuscript on essential components for a multidisciplinary program in support of patients with thrombotic and hemorrhagic disorders 97. In July of 2007, the Thrombosis and Hemostasis Centers Research and Prevention Network was established to further epidemiologic and clinical research investigations in thrombosis and thrombophilia (and their associated complications). For more information, please see www.cdc.gov/ncbddd/hbd/clotting.htm.

### Government-Professional Society Collaboration

In February 2003, the APHA and CDC convened 60 of the nation’s leading medical experts and patient advocates in Washington, DC for a Public Health Leadership Conference on DVT. The purpose of the conference was to highlight the urgency of increased diligence related to disease prevention on the part of the healthcare community, as well as the need to raise awareness of DVT/PE and its complications among the general public. The conference identified several areas in need of immediate attention for education about these conditions:

- Create a national coalition to advocate for greater awareness of DVT/PE among health care professionals and the general public.
- Enlist the support of medical, professional, and patient advocacy organizations to make awareness part of their agendas.
- Develop a public awareness campaign and communication tools to educate consumers about the risk factors, symptoms, and prevention measures.
- Encourage state medical licensing boards to include DVT/PE in their CME/CE licensing renewal requirements.
- Close the gap between clinical practice guidelines for prophylaxis and actual practice through the creation and implementation of institutional standards.
- Encourage academic centers to incorporate education into curricula for all medical professionals.
- Ask accreditation and “standardization” institutions to ensure that healthcare providers and institutions implement clinical practice guidelines for prevention.
- Encourage the Joint Commission to make adherence to prevention guidelines part of its accreditation process.
- Educate policymakers about the cost-effectiveness of prevention and treatment of these conditions.

### Public-Private Sector Collaboration

The Centers for Medicare and Medicaid Services (CMS) and the Joint Commission have joined together to adopt standardized performance measures for hospitals to report. The DVT/ PE quality measures initiative is expected to become a CMS required reportable item, thus allowing CMS to benchmark hospitals’ care of these diseases against best performance.

Other examples can be found in the proceedings of the Surgeon General’s Workshop on Deep Vein Thrombosis.