# SECTION IV: A Call to Action: A Public Health Response to Reducing DVT and PE

DVT and PE are major public health problems in the United States. Much is known about how to reduce their burden, yet this knowledge is not being applied systematically today. Without a concerted effort to stem this public health crisis, the incidence and burden of these diseases will only grow larger as the population ages.

In May 2006, the Surgeon General hosted a workshop on DVT. This meeting began a developmental process that led to this “Surgeon General’s Call to Action.” A menu of important actions has been assembled from the presentations, discussion, and comments that were made during that Surgeon General’s Workshop. This menu, which is presented in the following section, highlights areas that received significant attention during the workshop and in background papers prepared by scientists and clinicians who participated in the workshop 94. Although not meant to be prescriptive recommendations, the menu should establish useful starting points for consideration as individuals and groups focus their own skills, creativity, and inspiration on reducing the public health crisis of DVT and PE.

The discussions at the Surgeon General’s Workshop centered on research, activities, and interventions in three settings: communities, the health care system, and governments. The key actions discussed are presented for each of these settings, although many of these actions can be applied in all of the settings.

The key actions are organized by a framework called CARE: Communication, Action, Research, and Evaluation.

- Communication refers to the provision of information and tools to motivate and empower decisionmakers within the various settings to create change that will lead to more effective prevention, diagnosis, and treatment of first-time and recurrent DVT/PE.
- Action refers to interventions and activities that will assist various stakeholders in preventing, diagnosing, and treating the diseases more effectively.
- Research and evaluation refers to scientific investigations that will allow for a better understanding of issues that are currently not well understood related to the prevention, diagnosis, and treatment of these conditions.

## Setting 1: Communities

Individuals, families, and their communities need to understand DVT and PE, the risk factors for these diseases, and how to reduce these risks. They also need to recognize the signs and symptoms and know about available treatments. Patients and family members should proactively discuss these conditions when interacting with their health care providers. The goal is to raise awareness among patients and family members and empower them to ask their physicians about preventive treatment during hospitalization, after a traumatic event, or in other high-risk situations.

A broad-based communications program can play a major role in raising awareness. From a public education and social marketing standpoint, communications programs can disseminate health messages aimed at educating individuals about DVT/PE and the fact that anyone can be at risk for them. These messages can highlight the symptoms, warning signs, triggering events, and risk factors associated with these conditions.

One approach that an outreach effort can take is to work with various media, including the Internet, to help fill an important gap that exists today in the availability of appropriate educational materials.

A recent survey found that individuals and family members of those who have had a clot or who suffer from thrombophilia are interested in a variety of topics, most notably prevention, treatment, insurance issues; signs and symptoms of the disease; risk factors; genetics; general information on clots; and local, national, and regional resources to support those at risk or who have DVT/PE 95. An evaluation of available educational materials found that very few, if any, appropriate materials on these high-interest topics exist 96.

Community-based and national advocacy organizations can potentially play a critical role in helping individuals become more knowledgeable and empowered. Many of these organizations are already actively involved in this effort, and their work needs to be supported and expanded. Emphasis should be placed on family and community opportunities for communication and actions that will raise awareness of DVT/PE among the public at large and among specific, high-risk groups.

#### Initiating a Communications Campaign: A Case Example

The Coalition to Prevent DVT (The Coalition) established March 2004 as the first DVT Awareness Month. This month-long campaign included a celebrity spokesperson in conjunction with print media coverage, a satellite media tour, and a television public service announcement (PSA) that reached millions of Americans. The following year, the U.S. Senate passed Resolution 56, declaring March as DVT Awareness Month. In March 2005 representatives from The Coalition were seen on “Larry King Live,” the “Today Show,” and the “Jane Pauley Show.” A campaign PSA reached an additional 37 million people. Patient stories were the focus for DVT Awareness Month 2006, and the Coalition is currently preparing a book of patient stories for release by primary author Melanie Bloom, widow of NBC journalist David Bloom who died suddenly of a PE while covering the war in Iraq.

### Communication

- Raise consumer awareness about DVT/PE and the magnitude of the burden caused by these conditions.
- Educate consumers about symptoms, risk factors, and triggering events, especially surgery, hospitalization, and trauma.
- Raise consumer awareness about genetic predispositions to DVT/PE
- Promote the use of messages in news reports that educate the public by sharing information on the magnitude of the problem, both in terms of incidence and mortality/morbidity.
- Disseminate to the public through news outlets and the Internet individual patient stories, as these stories can often have more impact than statistics alone.
- Emphasize the fact that there exists a large gap between what is known about how to prevent and treat DVT/PE and what is happening in practice today.
- Facilitate the development and dissemination of uniform messages about DVT/PE that are consistent with existing guidelines.

### Action

- Form community coalitions to sponsor public awareness campaigns.
- Develop tools and materials that patients can use when talking with their physicians and other health professionals.
- Create local networks and peer support programs for patients and their family members.
- Work with volunteer groups, professional societies, and the media as part of a national awareness campaign intended to educate both the public and health professionals about the incidence of the disease, along with its symptoms and risk factors.
- Make available to the media accurate messages about DVT/PE for news stories and media programming, including television shows.
- Encourage community-based advertising campaigns.
- Consider using a celebrity spokesperson to deliver messages about these conditions, especially a celebrity who may have had a personal experience related to either DVT or PE.

### Research and Evaluation

- Gain a better understanding of what the public already knows about DVT/PE, gaps in their understanding, and how best to address those gaps.
- Develop and test messages to determine which approaches work best to educate the public, inform them of when they are at risk, and empower them to raise issues proactively with their clinicians.
- Investigate, in a culturally and linguistically appropriate manner, why certain ethnic groups are more or less likely to develop these conditions.
- Investigate the causes of age- and gender- based variations in the incidence and recurrence of these diseases, including why men are more susceptible to a recurrence.
- Research the role that behavior modification (e.g., smoking cessation, increased physical activity, better diet, weight loss) plays, if any, in reducing risk.
- Conduct research to better understand why obesity increases risk.
- Investigate the role that prolonged immobility due to travel (air, car, rail), hospitalization, or nursing home confinement plays in increasing risk.
- Conduct an analysis of the economic toll of DVT/PE on individuals, families, communities, and the nation as a whole. This analysis should include not only the direct costs (i.e., healthcare expenditures), but also indirect costs such as lost productivity and wages due to time away from work.
- Evaluate the impact of communication and social marketing programs, including pre- and post-evaluation levels of consumer awareness and knowledge.
- Conduct formative research to ensure that media messages are positive, realistic, relevant, consistent, and effective.

## Setting 2: The Health Care System

The health care system is uniquely positioned to implement interventions aimed at reducing the incidence and burden of DVT/PE. The majority of cases occur within the health care system, for example, during surgery, hospitalization, or treatment for trauma. Although much is known about effiective prevention and treatment, this evidence is not being applied in a systematic way.

Hospitals, health systems, medical schools and residency programs, researchers, universities, primary care and specialty group practices, physicians, nurses, and allied health professionals have a critical role to play in preventing and reducing the burden of DVT/PE. There is much work to be done—both to better apply evidence-based medicine in real-world settings today, and to investigate the many gaps in knowledge related to the basic and clinical science surrounding these diseases. Insurers, health plans, and other public and private purchasers also have a critical role to play in establishing payment policies that encourage the provision of high-quality, evidence-based care.

### Communication

- Inform health care professionals and administrators about the problem of DVT/ PE in terms of mortality, morbidity, and direct and indirect costs.
- Promote evidence-based practice by sharing existing guidelines with appropriate professionals on the prevention, diagnosis, and treatment in specific populations.
- Promote the findings and recommendations from groups such as the IOM, AHRQ, Joint Commission, and NQF related to the importance of screening all hospitalized patients for risk for these diseases, and providing appropriate preventive treatment based on those screenings.
- Raise awareness of current agency and organizational guidelines in relation to preferred practices and performance measures.
- Educate health professionals about the availability of genetic testing, when it may be appropriate to discuss with and test patients, and the importance of counseling for those who test positive.
- Educate primary care physicians and specialists about the true, relative risks of excessive bleeding from properly managed anticoagulation therapy versus the risks of not using such therapy.
- Inform health care providers about the availability and appropriate use of treatment options, including anticoagulation therapy and clot-dissolving/clot-removal therapies.

### Action

- Convene cross-disciplinary forums to forge consensus on a single set of clear, standardized, evidence-based guidelines in those areas where multiple and/or conflicting guidelines currently exist.
- Institute formal systems related to risk assessment and the provision of preventive therapy (prophylaxis) to appropriate high-risk individuals in the hospital and community.
- Consistently track performance on current and future DVT measures that are endorsed by NQF, and develop quality improvement initiatives designed to improve performance on these measures over time.
- Develop and improve easy-to-use tools (e.g., reminder systems) that provide ready access to relevant data and information at the point of care. These tools help practitioners to follow existing evidence-based guidelines.
- Develop and/or refine tools and/or algorithms to determine who should undergo diagnostic imaging tests for DVT/PE. These tools could incorporate clinical manifestations, biomarkers and genetic profiles, patient and family history, the results of simple mechanical tests, and other information to determine who should be screened.
- Identify and support physician champions who can encourage their peers to provide evidence-based preventive, diagnostic, and therapeutic care.
- Encourage the development of new pharmaceutical agents that have fewer drawbacks than existing medications. The goal is to find agents with faster onset, a wider therapeutic range (thus reducing the need for frequent testing or monitoring of dosage), and fewer food and drug interactions.
- Encourage medical, nursing, and pharmacy schools, and residency programs to provide adequate classroom education and training to ensure that new physicians, nurses, and pharmacists are aware of the magnitude of the problem and how to prevent, diagnose, and treat DVT/PE in accordance with the latest scientific evidence.
- Encourage medical, nursing, and pharmacy schools, and residency programs to develop more formalized programs for training students and residents who might be interested in becoming thrombosis specialists.
- Encourage medical, nursing, and pharmacy schools, and other organizations to incorporate training into continuing medical education, certification, and recertification processes.
- Review payment policies to ensure that they provide appropriate reimbursement for high-quality, evidence-based care.
- Support the development of hospital- and community-based support programs for patients with DVT/PE and their family members.
- Analyze the merits of innovative approaches to anticoagulation therapy management, including, but not limited to, anticoagulation clinics and patient self-testing/management.
- Develop and/or encourage physicians, nurses, and other health professionals to attend education programs related to all aspects of DVT/PE.
- Support the training of investigators and providers by sponsoring fellowships and other training opportunities.

### Research and Evaluation

- Conduct further research into the benefits and risks associated with various strategies (pharmacological, mechanical, and surgical) for dissolving or removing clots, and to determine which patients, if any, would benefit from these approaches (as an alternative to anticoagulation therapy).
- Conduct further research into the pathophysiology of DVT/PE, including the roles of inflammation, obesity, stasis, and the basic endothelial cell biology and vessel response to stasis and thrombosis. This research can lead to the development of novel prevention and treatment strategies.
- Investigate whether biomarkers can be identified that will allow for the development of individualized risk profiles for primary and recurrent DVT/PE, and chronic venous insufficiency. These biomarkers can be used to help predict an individual’s response to therapy.
- Investigate the role of prolonged air, car, or rail trips (and other situations causing long periods of immobility) on raising risk, both for the general population and certain high-risk groups, such as women on oral contraceptives or individuals with a genetic predisposition to DVT/PE.
- Investigate the role of compression ultrasonography (CUS) in diagnosing isolated calf DVT, and study the benefits and costs associated with treatment.
- Study the effectiveness of the D-dimer test in diagnosing recurrence of the disease.
- Investigate the safety and effectiveness of various approaches to diagnosing DVT/ PE in pregnant women.
- Conduct further research into the best drugs, dosing strategies, and treatment regimens for anticoagulation therapy for certain patient populations, including children (from infancy through adolescence), obese individuals, and those with renal insufficiency.
- Conduct further research on the benefits and risks of preventive and therapeutic anticoagulation therapy for certain patient populations, including children, pregnant women, individuals with a genetic predisposition to DVT/PE (with or without prior events), cancer patients, and the elderly. Such research should also address how to treat individuals with multiple risk factors, such as pregnant women or children with genetic predisposition.
- Conduct further research into the appropriate duration of anticoagulation therapy in specific patient populations, including whether some high-risk groups should remain on the therapy indefinitely.
- Investigate the role that pharmacogenetics can play in determining optimal warfarin dosing in individuals.
- Investigate the role of inferior vena caval (IVC) filters as a primary means of preventing PE, and research the risks and benefits related to permanent versus retrievable placement of IVC filters.
- Investigate and evaluate the various approaches (e.g., pharmacological, mechanical, and/or a combination) to reducing the risk and impact of chronic venous insufficiency.
- Investigate the risks and benefits of using clot-dissolving medications in patients with PE.
- Conduct research into when genetic testing is appropriate, including whether and when to test the asymptomatic family members of those with a genetic predisposition to DVT/PE.
- Conduct further research into the optimal therapy for those with genetic predisposition, and how that therapy might vary depending upon the number of genetic and other acquired risk factors or triggering events. Research should focus on the impact of specific thrombophilic disorders on anticoagulant therapy management and the identification of optimal prophylactic strategies for asymptomatic individuals during high-risk situations.
- Conduct research into how upper extremity DVT—a less common and less studied form than DVT in the legs—should best be evaluated, diagnosed, and managed.

## Setting 3: Policymakers and Governments

Policymakers and various branches of local, tribal, state, and national governments also have a critical role to play in raising awareness and encouraging the development and use of evidence-based guidelines.

### Communication

- Raise policymakers’ awareness of DVT/PE and the magnitude of the problems caused by the disease, as well as the need to support research, infrastructure, and payment policies that are consistent with the provision of evidence-based care.
- Support public awareness campaigns, including DVT Awareness Month activities.
- Support the education of health professionals, including the dissemination of evidence-based guidelines.

### Action

- Review reimbursement policies to ensure that they encourage the provision of evidence- based prevention, diagnosis, and treatment.
- Support the formation of community-based, regional, and national multistakeholder coalitions dedicated to raising awareness about these diseases.
- Form task forces, steering committees, or advisory committees dedicated to addressing the problems resulting from these conditions.
- Support actions that lead to enhanced public awareness about DVT/PE among health professionals and greater adherence to evidence-based practices.

### Research and Evaluation

- Support basic, clinical, and epidemiological research that is intended to fill critical gaps in today’s knowledge about DVT/PE.
- Support translational research and the development of other tools that are intended to speed the adoption of new scientific knowledge into the everyday practice of medicine.
- Support the training of scientific investigators and providers who are interested in these diseases.