# SECTION III: Gaps in Application and Awareness of Evidence-based Interventions

As discussed in the previous section, much is already known about how to prevent and treat DVT/PE. Yet the human and economic toll on both individuals and society as a whole remains high. Left unchecked, the aging of the population will increase this burden over time. Why do DVT and PE remain such serious problems, particularly given the availability of effective strategies for preventing and minimizing them? The answer lies primarily in the failure to consistently use evidence-based interventions in those high-risk individuals who need them. This failure may be due to clinicians’ lack of awareness, and consistent adherence to evidence-based practices. An additional factor is a health care system that may not consistently provide coverage for the provision of high-quality preventive and therapeutic treatment.

## Application of Guidelines

A substantial body of evidence suggests that evidence-based DVT/PE guidelines are not being routinely followed. Most of this evidence relates to prophylaxis, although some data on treatment exist as well. High-risk patients and those with identifiable symptoms are not routinely receiving prophylaxis that could help to prevent the development of DVT and/or PE. A large epidemiological study of 5,451 patients with ultrasound-confirmed DVT (seen at 183 different clinical sites) found that the majority had been given no prophylaxis prior to their diagnosis despite being at high risk. Men were 21 percent more likely than women to have received prophylaxis 82. In other words, high-risk patients (especially women) are not being identified in a timely manner and provided with appropriate therapy designed to prevent the development of DVT/PE.

This finding is consistent across all age groups, in both academic and community hospitals, and throughout all regions of the United States. The gender difference persists even after adjusting for cancer, surgery, prior DVT, trauma, and age 83.

Other studies also confirm the failure to routinely provide preventive treatment to high-risk patients. A study of 2,017 patients in 16 short-stay Massachusetts hospitals found that only 32 percent of high-risk patients received appropriate prophylaxis, with rates across the hospitals ranging from 9 percent to 56 percent 84. A recent small study of 44 medical and surgical patients found that 38.6 percent of those who were classified as having potentially preventable VTE did not receive adequate prophylaxis 85.

The failure to provide preventive therapy is not limited to the United States. A study of 446 medical patients at two teaching hospitals in Hamilton, Ontario found very similar results, with only one-third of high-risk patients receiving some form of prophylaxis 86. While high-risk surgical patients appear to be more likely to receive prophylaxis than high-risk medical patients, preventive therapy remains underused in this population as well. A study of 1,907 high-risk surgical patients at 10 teaching and community-based hospitals found that 93.7 percent of high-risk orthopedic surgery patients and 75.2 percent of high-risk abdominal surgery patients received appropriate prophylaxis 87. Another study found that 14.4 percent of high-risk orthopedic surgery patients received inadequate preventive therapy or none at all. The same study found that orthopedic surgery patients who do get anticoagulation therapy typically receive it for only three to five days.

This is in stark contrast to current recommendations, which suggests a minimum of seven to 10 days and perhaps as long as 30 days for these patients 88.

Lack of adherence to guidelines extends beyond preventive therapy to treatment of the disease as well. A 2005 study of 3,778 patients at 38 academic/teaching, community, and Veterans Administration hospitals concluded that in just under one-half of patients with DVT, PE, or both, anticoagulation therapy was discontinued too early. In addition, patients with DVT or PE were rarely discharged from the hospital with appropriate bridge therapy (an injectable anticoagulation agent plus warfarin) 89. The reasons for poor adherence to established guidelines and standards are not entirely clear, although a variety of factors may be at play, including clinical concerns and other issues.

As noted earlier, one of the major themes of “The Surgeon General’s Workshop on DVT” was the issue surrounding potential inconsistencies, conflicts, and ambiguities within and across the many different guidelines that exist today. Some clinicians may not be aware of existing guidelines, or may not believe that the evidence supporting them is adequate. Some time-pressed clinicians may inadvertently overlook existing guidelines, while those in some specialties may feel uncomfortable using anticoagulant therapy due to the potential risk of bleeding.

Whatever the reasons for poor adherence, the good news is that effective strategies appear to be available to support clinicians in their efforts to practice evidence-based care. A recent meta-analysis of 30 U.S. and international studies evaluating various strategies for increasing the use of prophylaxis came to the following conclusions 90:

- Passive strategies (such as guideline dissemination by means of international or local publication) resulted in poor adherence to guidelines, with no more than half of patients receiving appropriate prophylaxis.
- More proactive strategies resulted in significantly higher adherence rates. These included computer-based clinical decision support systems, audit and feedback, documentation aids, and active monitoring of DVT/ PE prophylaxis policies. Computer-based decision support resulted in nearly 100 percent compliance with guidelines, while the other strategies resulted in roughly 80 percent compliance. (See box below for a case example of a computerized reminder system that boosted use of prophylaxis and significantly reduced the incidence of both DVT and PE.)
- The use of multiple strategies consistently resulted in improved adherence to guidelines. Based on these findings, the authors of this study recommend a multipronged approach to increasing use of prophylaxis, including the following elements: continuing education to improve clinician knowledge of DVT/PE risk assessment and appropriate prophylaxis; documentation and/or computer-based systems to remind clinicians to assess risk and assist in prescribing appropriate prophylaxis; and ongoing assessment of the effectiveness of existing policies and interventions, with refinements as necessary 91.

### Public Awareness about DVT

The American Public Health Association (APHA) commissioned a telephone survey of over 1,000 American adults to determine current levels of awareness of DVT among the public. The study found that DVT was the least known of the mentioned diseases and conditions, with less than a quarter of respondents having heard of the disease, compared to 93 percent who had heard of diabetes and allergies and 91 percent who had heard of stroke. Even colitis—at 42 percent awareness levels—was better known than DVT. Males, those under the age of 35, and those with lower levels of education were more likely to be unaware of DVT 93.

##### Computerized Reminders to Boost Adherence

While a variety of strategies are available to encourage physicians to adhere to evidence-based guidelines, one of the most effective appears to be electronic reminders that alert physicians to the potential need for a particular course of action based on the evidence. Brigham and Women’s Hospital (BWH) used this approach with physicians whose high-risk patients were not receiving DVT prophylaxis. BWH conducted a randomized controlled trial of 2,506 patients, with 1,255 in the intervention group (i.e., patients whose physicians received an alert) and 1,251 in the control group (i.e., patients whose physicians did not receive an alert) 92. The study found that 33.5 percent of high-risk patients in the intervention group received DVT prophylaxis, compared to 14.5 percent in the control group. While both figures are too low, the computerized system clearly helped improve adherence dramatically. More importantly, this improved adherence led to a 41 percent lower incidence of symptomatic disease among patients in the intervention group, as compared to those in the control group. Subsequent monitoring of the alert system has found that physicians are now ordering prophylaxis in response to the alert 40 percent of the time, suggesting that further improvement in physician adherence has occurred. Additional testing and analysis of strategies to further improve adherence rates are warranted.

It is important to note that the beneficial effect of the electronic alert system can potentially be replicated without computer support. A nurse, physician, or pharmacist could conduct patient rounds on all overnight admissions, review their charts, and determine whether specific patients are at high risk for developing DVT/PE during hospitalization. They could then review the written physician orders to determine whether prophylaxis had been instituted. For high-risk patients not receiving prophylaxis, the reviewer could page the responsible physician, point out the patient’s high risk, note the absence of prophylaxis orders, and suggest implementation of preventive measures.

Among the one-quarter of the queried population with at least some awareness of the disease, less than half were familiar with any signs or symptoms of the disease (46 percent), had any knowledge of risk factors (43 percent), or knew that DVT could be prevented (25 percent) 93. In other words, only about 1 in 10 Americans know about DVT and are familiar with its symptoms and/or risk factors, and only about six percent of Americans know what it is and that it can be prevented.

##### The Importance of Educating the Public: David Bloom’s Story

David Bloom died in April 2003 at the age of 39 while covering the war in Iraq as a reporter for NBC News. An avid tennis player who was in great health, he was subject to prolonged periods of immobility and dehydration in Iraq, often having to spend many hours inside a cramped tank. Unknown to David, he had an inherited blood coagulation disorder along with other acquired risk factors for DVT. Two nights before his death, David spoke with his wife, Melanie, on the telephone, telling her that his legs hurt because they had been cramped up inside the tank for too long. He told her that he was planning to sleep outside that night because he could not bear to be cooped up for another night. Having heard that he planned to sleep out in the open naturally made Melanie fear for his safety.

Two days later, as a result of DVT, a massive blood clot traveled from David’s leg to his lungs resulting in a PE that killed him almost instantly. He was a victim not of the war’s violence, but rather of a lack of awareness about DVT. Had he, his loved ones, or those around him been aware of the risk factors and warning signs, and had he known about his genetic predisposition to the disease, his life might have been saved. Melanie has now made it her mission to educate the public about DVT so that others will not die unnecessarily.