# SECTION II: Reducing the Risk for DVT/ PE

Much is known today about how to prevent DVT/PE, and how to minimize the impact for those patients who suffer from these conditions. If this knowledge were applied consistently, the burden could be reduced substantially. Unlike other chronic diseases, there is at present little evidence on the impact of lifestyle changes on the risk for DVT/PE. While being overweight and smoking are known risk factors, it is not yet known whether smoking cessation, weight loss, increased physical activity, or other lifestyle changes significantly reduce risk. A recent study did find that a diet that includes more fruits, vegetables, and fish, and less red and processed meat is associated with a lower incidence of DVT/PE 77. But further studies on the impact of diet and other lifestyle changes are warranted.

As noted earlier, about half of those who develop DVT/PE have two things in common. First, they have one or more identifiable risk factors for the disease. Second, they experience some sort of triggering event, such as hospitalization, trauma, surgery, or a prolonged period of immobilization (e.g., due to nursing home confinement or a long trip by air, car, or train) that leads to the formation of one or more blood clots. The other half of those who get the disease have “unprovoked DVT/PE”—that is, the reasons for the events are unknown. There is much that can be done, however, to prevent high-risk individuals from developing these conditions. Providing preventive treatment (or primary prophylaxis) to these individuals can dramatically reduce the likelihood of a blood clot or PE.

Several drugs have been found to be effective in reducing the likelihood of a blood clot in high-risk individuals. These drugs are known as anticoagulants or blood thinners because they slow down the coagulation processes, and thus reduce the likelihood that a blood clot will form. Numerous studies over a long period of time confirm the benefits of using blood-thinning medications as a preventive measure in high-risk individuals.

Addtionally, several mechanical devices exist to help prevent DVT and/or PE. These devices are often used for individuals who are at risk but are not able to tolerate anticoagulants. Mechanical devices deliver variable gradations of external pressure around the circumference of the leg to improve venous circulation.

Another preventive therapy option is the use of a permanent or retrievable implantable filter in the vena cava. These filters act like miniature umbrellas with holes that can trap blood clots—and thus prevent PE—without stopping the flow of blood. They have been used with success in a variety of patients, including those whose anticoagulation therapy must be stopped due to the need for urgent surgery, patients undergoing bariatric surgery, and patients who suffer multiple injuries from a motor vehicle accident. It is important to note, however, that these filters do not prevent DVT. Rather, they are designed to help prevent PE in those who are at high risk of DVT.

## Existing Evidence-Based Guidelines, Standards, and Measures for DVT/PE

A search was conducted of the National Guidelines Clearinghouse™ (NGC), a comprehensive database of evidence-based clinical practice guidelines and related documents created by the Agency for Healthcare Research and Quality (AHRQ) in partnership with the American Medical Association and American Association of Health Plans. The search was conducted at www.guideline.gov on June 27, 2006, and more than 100 guidelines related to PE and DVT were found. The initial search on the term “pulmonary embolism” produced 111 guidelines. While searching on the term “deep vein thrombosis” 88 guidelines were produced and the vast majority duplicated the initial search. These guidelines cover a wide variety of topics related to preventing, diagnosing, and treating DVT/ PE in general and specific populations. Multiple guidelines exist related to certain common issues, such as when and how to provide preventive treatment or prophylaxis. While all guidelines included in the NGC are based on scientific evidence, the strength of the evidence behind these guidelines varies. The NGC includes a summary of the strength of the evidence that underlies each guideline that is included in the clearinghouse.

The clearest consensus in the guidelines exists on the need to screen hospitalized patients for risk of DVT/PE and to provide appropriate prophylaxis to those at risk. The Institute of Medicine 1999 landmark report on medical errors noted that failure to provide prophylactic therapy when indicated is a hospital error 78. AHRQ has evaluated and ranked the effectiveness of 79 safety practices based on strength of evidence, and found prevention to be the highest-ranked of all the practices evaluated 79. Based on this finding, the National Quality Forum (NQF) now recommends that all hospitalized patients be evaluated upon admission and regularly thereafter, and that those found to be at risk be given prophylaxis for VTE 80.

Guidelines from the American College of Chest Physicians provide recommendations on what prophylaxis regimen to give to hospitalized patients with varying levels of risk factors. Regimens may range from early, aggressive ambulation to a combination of anticoagulation therapy, intermittent pneumatic compression, and/or graduated compression stockings.

### Consensus Standards for Prevention and Care of DVT/PE

In May 2006, the National Quality Forum NQF endorsed a set of 20 national voluntary consensus standards around model policies, practices, and performance measures related to the prevention and care of VTE. This set of 20 standards, which had been developed under the leadership of the Joint Commission (formerly known as the Joint Commission on the Accreditation of Healthcare Organizations), includes a policy statement recommending that every healthcare facility have a written, evidence-based policy to drive quality improvement related to risk assessment, prevention, diagnosis, and treatment. It also contains 17 key characteristics of preferred practices including general recommendations and practices related to risk assessment/stratification, prevention, diagnosis, and treatment/monitoring. In addition there are two performance measures that can be used for public reporting 81. The two measures relate to ordering and providing preventive treatment to hospitalized surgical patients. The specific measures are as follows:

- Surgery patients with recommended prophylaxis ordered
- Surgery patients who receive appropriate prophylaxis within 24 hours prior to surgery to 24 hours after surgery

The Joint Commission is still in the process of developing additional measures, and their work is expected to be completed shortly. NQF will then consider endorsing these additional measures.

As noted, guidelines have been produced by a variety of organizations, often representing different medical specialties. Many researchers and clinicians who spoke at the Surgeon General’s Workshop on DVT noted that some of the guidelines may conflict with each other or are confusing. The result is that clinicians may find it difficult to use the guidelines in everyday practice. It is critical, therefore, that stakeholders involved in guideline development come together to produce—to the extent possible based on today’s best evidence—a more unified, synthesized, and clear set of guidelines related to the prevention, diagnosis, and treatment of DVT/PE in specific patient populations.