# References

1 Lawrence RA, Lawrence RM. Breastfeeding: a guide for the medical profession. 7th ed. Philadelphia. Saunders. 2010.
2 Ip S, Chung M, Raman G, Chew P, Magula N, DeVine D, et al. Breastfeeding and maternal and infant health outcomes in developed countries: evidence report/technology assessment no 153. Rockville, MD. Agency for Healthcare Research and Quality. 2007. AHRQ Publication No 07-E007.
3 Chien PF, Howie PW. Breast milk and the risk of opportunistic infection in infancy in industrialized and non-industrialized settings. Adv Nutr Res. 2001;10:69-104. [pmid: 11795054].
4 Bachrach VR, Schwarz E, Bachrach LR. Breastfeeding and the risk of hospitalization for respiratory disease in infancy: a meta-analysis. Arch Pediatr Adolesc Med. 2003;157:237-243. [pmid: 12622672].
5 Kwan ML, Buffler PA, Abrams B, Kiley VA. Breastfeeding and the risk of childhood leukemia: a meta-analysis. Public Health Rep. 2004;119:521-535. [pmid: 15504444].
6 Owen CG, Martin RM, Whincup PH, Smith GD, Cook DG. Does breastfeeding influence risk of type 2 diabetes in later life? A quantitative analysis of published evidence. Am J Clin Nutr. 2006;84:1043-1054. [pmid: 17093156].
7 Arenz S, Ruckerl R, Koletzko B, von Kries R. Breastfeeding and childhood obesity—a systematic review. Int J Obes Relat Metab Disord. 2004;28:1247-1256. [pmid: 15314625].
8 Collaborative Group on Hormonal Factors in Breast Cancer. Breast cancer and breastfeeding: collaborative reanalysis of individual data from 47 epidemiological studies in 30 countries, including 50302 women with breast cancer and 96973 women without the disease. Lancet. 2002;360:187-195. [pmid: 12133652].
9 Bernier MO, Plu-Bureau G, Bossard N, Ayzac L, Thalabard JC. Breastfeeding and risk of breast cancer: a meta-analysis of published studies. Hum Reprod Update. 2000;6:374-386. [pmid: 10972524].
10 Chung M, Raman G, Trikalinos T, Lau J, Ip S. Interventions in primary care to promote breastfeeding: an evidence review for the U.S. Preventive Services Task Force. Ann Intern Med. 2008;149:565-582. [pmid: 18936504].
11 Gdalevich M, Mimouni D, David M, Mimouni M. Breastfeeding and the onset of atopic dermatitis in childhood: a systematic review and meta-analysis of prospective studies. J Am Acad Dermatol. 2001;45:520-527. [pmid: 11568741].
12 Bai YK, Middlestadt SE, Joanne Peng CY, Fly AD. Psychosocial factors underlying the mother’s decision to continue exclusive breastfeeding for 6 months: an elicitation study. J Hum Nutr Diet. 2009;22:134-140. [pmid: 19302118].
13 Guttman N, Zimmerman DR. Low-income mothers’ views on breastfeeding. Soc Sci Med. 2000;50:1457-1473. [pmid: 10741581].
14 Neifert M, Gray J, Gary N, Camp B. Factors influencing breastfeeding among adolescents. J Adolesc Health Care. 1988;9:470-473. [pmid: 3182360].
15 O’Hara MW, Swain AM. Rates and risk of postpartum depression—a meta-analysis. Int Rev Psychiatry. 1996;8:37-54.
16 Mancini F, Carlson C, Albers L. Use of the Postpartum Depression Screening Scale in a collaborative obstetric practice. J Midwifery Women’s Health. 2007;52:429-434.
17 Green K, Broome H, Mirabella J. Postnatal depression among mothers in the United Arab Emirates: sociocultural and physical factors. Psychol Health Med. 2006;11:425-431. [pmid: 17129919].
18 Jardri R, Pelta J, Maron M, Thomas P, Delion P, Codaccioni X, et al. Predictive validation study of the Edinburgh Postnatal Depression Scale in the first week after delivery and risk analysis for postnatal depression. J Affect Disord. 2006;93:169-176. [pmid: 16644021].
19 Dennis CL, McQueen K. The relationship between infant-feeding outcomes and postpartum depression: a qualitative systematic review. Pediatrics. 2009;123:e736-e751. [pmid: 19336362].
20 Ball TM, Wright AL. Health care costs of formula feeding in the first year of life. Pediatrics. 1999;103:870-876. [pmid: 10103324].
21 United States Breastfeeding Committee. Economic benefits of breastfeeding [issue paper]. Raleigh, NC. United States Breastfeeding Committee. 2002.
22 U.S. Department of Health and Human Services. Healthy people 2010. 2nd ed. Washington, DC. U.S. Government Printing Office. November. 2000.
23 Weimer J. The economic benefits of breastfeeding: a review and analysis, ERS Food Assistance and Nutrition Research Report No 13. Washington, DC. U.S. Department of Agriculture, Economic Research Service. 2001.
24 Bartick M, Reinhold A. The burden of suboptimal breastfeeding in the United States: a pediatric cost analysis. Pediatrics. 2010;125:e1048-e1056. [pmid: 20368314].
25 Gartner LM, Morton J, Lawrence RA, Naylor AJ, O’Hare D, Schanler RJ, Eidelman AI. American Academy of Pediatrics Section on Breastfeeding. Breastfeeding and the use of human milk. Pediatrics. 2005;115:496-506. [pmid: 15687461].
26 La Leche League International. The womanly art of breastfeeding. USA. Penguin Books. 1995.
27 American Academy of Family Physicians. Breastfeeding (policy statement). 2007. Available at: http://www.aafp.org/online/en/home/policy/policies/b/breastfeedingpolicy.html. Accessed July 2, 2010.
28 American College of Obstetricians and Gynecologists, Committee on Health Care for Underserved Women, and Committee on Obstetric Practice. ACOG committee opinion #361: breastfeeding: maternal and infant aspects. Obstet Gynecol. 2007;109(2Pt1):479-480. [pmid: 17267864].
29 American College of Nurse-Midwives, Division of Women’s Health Policy and Leadership. Position statement: breastfeeding. 2004. Available at: http://www.midwife.org/siteFiles/position/Breastfeeding_05.pdf. Accessed July 2, 2010.
30 James DC, Lesson R. American Dietetic Association. Position of the American Dietetic Association: promoting and supporting breastfeeding. J Am Diet Assoc. 2009;109:1926-1942. [pmid: 19862847].
31 American Public Health Association. A call to action on breastfeeding: a fundamental public health issue. Policy No. 200714. Available at: http://www.apha.org/advocacy/policy/policysearch/default.htm?id=1360. Accessed July 2, 2010. 2007;59.
32 U.S. Department of Health and Human Services. Report of the Surgeon General’s workshop on breastfeeding & human lactation. Washington, DC. U.S. Department of Health and Human Services. 1984. Publication No. HRSD- MC 84–2.
33 U.S. Department of Health and Human Services. Followup report: the Surgeon General’s workshop on breastfeeding and human lactation. Washington, DC. U.S. Department of Health and Human Services. 1985. Publication No. HRS-D-MC 85–2.
34 Spisak S, Gross SS. Second followup to the Surgeon General’s workshop on breastfeeding and human lactation. Washington, DC. National Center for Education in Maternal and Child Health. 1991.
35 World Health Organization. International code of marketing of breast-milk substitutes. 1981. Available at: http://www.who.int/nutrition/publications/code_english.pdf. Accessed July 27, 2010.
36 United Nations Children’s Fund, World Health Organization. Innocenti declaration on the protection, promotion and support of breastfeeding. Florence, Italy. UNICEF/WHO. 1990.
37 U.S. Department of Health and Human Services. HHS blueprint for action on breastfeeding. Washington, DC. U.S. Department of Health and Human Services, Office on Women’s Health. 2000.
38 Martinez GA, Nalezienski JP. The recent trend in breastfeeding. Pediatrics. 1979;64:686-692. [pmid: 492844].
39 Ryan AS. The resurgence of breastfeeding in the United States. Pediatrics. 1997;99(4):e12. [pmid: 9099787].
40 Ryan AS, Wenjun Z, Acosta A. Breastfeeding continues to increase into the new millennium. Pediatrics. 2002;110:1103-1109. [pmid: 12456906].
41 Centers for Disease Control and Prevention. Breastfeeding among U.S. children born 1999–2007, CDC National Immunization Survey. Available at: http://www.cdc.gov/breastfeeding/data/NIS_data/index.htm. Accessed August 2, 2010.
42 Fein SB, Labiner-Wolfe J, Shealy KR, Li R, Chen J, Grummer-Strawn LM. Infant Feeding Practices Study II: study methods. Pediatrics. 2008;122(Suppl 2):S28-S35. [pmid: 18829828].
43 Grummer-Strawn LM, Scanlon KS, Fein SB. Infant feeding and feeding transitions during the first year of life. Pediatrics. 2008;122(Suppl 2):S36-S42. [pmid: 18829829].
44 Academy of Breastfeeding Medicine Protocol Committee. ABM clinical protocol #3: hospital guidelines for the use of supplementary feedings in the healthy term breastfed neonate, revised 2009. Breastfeed Med. 2009;4:175-182. [pmid: 19739952].
45 Centers for Disease Control and Prevention. Racial and ethnic differences in breastfeeding initiation and duration, by state—National Immunization Survey, United States, 2004–2008. MMWR Morb Mortal Wkly Rep. 2010;59:327-334. [pmid: 20339344].
46 Grummer-Strawn LM, Shealy K. Progress in protecting, promoting, and supporting breastfeeding: 1984–2009. Breastfeeding Med. 2009;4:S31-S39.
47 Oyeku SO. A closer look at racial/ethnic disparities in breastfeeding. Commentary on “Breastfeeding advice given to African American and white women by physicians and WIC counselors. Public Health Rep. 2003;118:377-378. [pmid: 12815088].
48 Satcher DS. DHHS blueprint for action on breastfeeding. Public Health Rep. 2001;116:72-73. [pmid: 11571412].
49 Fein SB, Mandal B, Roe BE. Success of strategies for combining employment and breastfeeding. Pediatrics. 2008;122(Suppl 2):S56-S62. [pmid: 18829832].
50 Ortiz J, McGilligan K, Kelly P. Duration of breast milk expression among working mothers enrolled in an employer-sponsored lactation program. Pediatr Nurs. 2004;30:111-119. [pmid: 15185732].
51 Centers for Disease Control and Prevention. Breastfeeding trends and updated national health objectives for exclusive breastfeeding—United States, birth years 2000–2004. MMWR Morb Mortal Wkly Rep. 2007;56:760-763. [pmid: 17673896].
52 Centers for Disease Control and Prevention. Breastfeeding-related maternity practices at hospitals and birth centers—United States, 2007. MMWR Morb Mortal Wkly Rep. 2008;57:621-625. [pmid: 18551096].
53 Brown JD, Peuchaud SR. Media and breastfeeding: friend or foe?. Int Breastfeed J. 2008;3:15. [pmid: 18680582].
54 Bentley ME, Dee DL, Jensen JL. Breastfeeding among low income, African-American women: power, beliefs and decision making. J Nutr. 2003;133(Suppl):305S-309S. [pmid: 12514315].
55 Hausman B. Mother’s milk: breastfeeding controversies in American culture. New York. Routledge. 2003.
56 Beal AC, Kuhlthau K, Perrin JM. Breastfeeding advice given to African American and white women by physicians and WIC counselors. Public Health Rep. 2003;118:368-376. [pmid: 12815087].
57 Thulier D. Breastfeeding in America: a history of influencing factors. J Hum Lact. 2009;25:85-94. [pmid: 19196856].
58 Guendelman S, Kosa JL, Pearl M, Graham S, Goodman J, Kharrazi M. Juggling work and breastfeeding: effects of maternity leave and occupational characteristics. Pediatrics. 2009;123:e38-e46. [pmid: 19117845].
59 Mills SP. Workplace lactation programs: a critical element for breastfeeding mothers’ success. AAOHN J. 2009;57:227-231. [pmid: 19552337].
60 Kogan MD, Singh GK, Dee DL, Belanoff C, Grummer-Strawn LM. Multivariate analysis of state variation in breastfeeding rates in the United States. Am J Public Health. 2008;98:1872-1880. [pmid: 18703441].
61 McCann MF, Baydar N, Williams RL. Breastfeeding attitudes and reported problems in a national sample of WIC participants. J Hum Lact. 2007;23:314-324. [pmid: 17991796].
62 Li R, Rock VJ, Grummer-Strawn L. Changes in public attitudes toward breastfeeding in the United States, 1999–2003. J Am Diet Assoc. 2007;107:122-127. [pmid: 17197280].
63 Gibson ME. Getting back to basics: the curious history of breastfeeding in the United States. Am J Nursing. 2005;105:72c-73c.
64 Moore ER, Anderson GC, Bergman N. Early skin-to-skin contact for mothers and their healthy newborn infants. Cochrane Database Syst Rev. 2007(3):CD003519.
65 McFadden A, Toole G. Exploring women’s views of breastfeeding: a focus group study within an area with high levels of socio-economic deprivation. Matern Child Nutr. 2006;2:156-168. [pmid: 16881928].
66 Mozingo JN, Davis MW, Droppleman PG, Meredith A. “It wasn’t working.” Women’s experiences with shortterm breastfeeding. MCN Am J Matern Child Nurs. 2000;25:120-126. [pmid: 10810844].
67 Bunik M, Clark L, Zimmer LM, Jimenez LM, O’Connor ME, Crane LA, et al. Early infant feeding decisions in low-income Latinas. Breastfeed Med. 2006;1:225-235. [pmid: 17661603].
68 Gill SL, Reifsnider E, Mann AR, Villarreal P, Tinkle MB. Assessing infant breastfeeding beliefs among low-income Mexican Americans. J Perinat Educ. 2004;13:39-50. [pmid: 17273399].
69 Gill SL. Breastfeeding by Hispanic women. J Obstet Gynecol Neonatal Nurs. 2009;38:244-252.
70 Rivera AF, Dávila Torres RR, Parrilla Rodríguez AM, de Longo IM, Gorrín Peralta JJ. Exploratory study: knowledge about the benefits of breastfeeding and barriers for initiation in mothers of children with spina bifida. Matern Child Health J. 2008;12(6):734-738. [pmid: 17874287].
71 Li R, Fridinger F, Grummer-Strawn L. Public perceptions on breastfeeding constraints. J Hum Lact. 2002;18:227-235. [pmid: 12192957].
72 Dodgson JE, Duckett L, Garwick A, Graham BL. An ecological perspective of breastfeeding in an indigenous community. J Nurs Scholarsh. 2002;34:235-241. [pmid: 12237985].
73 McIntyre E, Hiller JE, Turnbull D. Community attitudes to infant feeding. Breastfeed Rev. 2001;9(3):27-33. [pmid: 11831688].
74 Libbus K, Bush TA, Hockman NM. Breastfeeding beliefs of low-income primigravidae. Int J Nurs Stud. 1997;34:144-150. [pmid: 9134470].
75 Zimmerman DR, Guttman N. “Breast is best”: knowledge among low-income mothers is not enough”. J Hum Lact. 2001;17:14-19. [pmid: 11847846].
76 Stewart-Knox B, Gardiner K, Wright M. What is the problem with breast-feeding? A qualitative analysis of infant feeding perceptions. J Hum Nutr Diet. 2003;16:265-273. [pmid: 12859708].
77 Dykes F, Moran VH, Burt S, Edwards J. Adolescent mothers and breastfeeding: experiences and support needs—an exploratory study. J Hum Lact. 2003;19:391-401. [pmid: 14620453].
78 Sikorski J, Renfrew MJ, Pindoria S, Wade A. Support for breastfeeding mothers: a systematic review. Paediatr Perinat Epidemiol. 2003;17(4):407-417. [pmid: 14629324].
79 Sussner KM, Lindsay AC, Peterson KE. The influence of acculturation on breast-feeding initiation and duration in low-income women in the US. J Biosoc Sci. 2008;40:673-696. [pmid: 18045509].
80 Gorman JR, Madlensky L, Jackson DJ, Ganiats TG, Boies E. Early postpartum breastfeeding and acculturation among Hispanic women. Birth. 2007;34:308-315. [pmid: 18021146].
81 Harley K, Stamm NL, Eskenazi B. The effect of time in the U.S. on the duration of breastfeeding in women of Mexican descent. Matern Child Health J. 2007;11:119-125. [pmid: 17279324].
82 Celi AC, Rich-Edwards JW, Richardson MK, Kleinman KP, Gillman MW. Immigration, race/ethnicity, and social and economic factors as predictors of breastfeeding initiation. Arch Pediatr Adolesc Med. 2005;159:255-260. [pmid: 15753269].
83 Gibson MV, Diaz VA, Mainous AG III, Geesey ME. Prevalence of breastfeeding and acculturation in Hispanics: results from NHANES 1999–2000 study. Birth. 2005;32:93-98. [pmid: 15918865].
84 Anderson AK, Damio G, Himmelgreen DA, Peng YK, Segura-Pérez S, Pérez-Escamilla R. Social capital, acculturation, and breastfeeding initiation among Puerto Rican women in the United States. J Hum Lact. 2004;20:39-45. [pmid: 14974699].
85 Rassin DK, Markides KS, Baranowski T, Richardson CJ, Mikrut WD, Bee DE. Acculturation and the initiation of breastfeeding. J Clin Epidemiol. 1994;47:739-746. [pmid: 7722587].
86 Romero-Gwynn E. Breast-feeding pattern among Indochinese immigrants in northern California. Am J Dis Child. 1989;143:804-808. [pmid: 2741851].
87 U.S. Government Accountability Office. Report to Congressional addressees: breastfeeding: some strategies used to market infant formula may discourage breastfeeding; state contracts should better protect against misuse of WIC name. Washington, DC. U.S. Government Accountability Office. 2006. Available at: http://www.gao.gov/new.items/d06282.pdf. Accessed July 26, 2010.
88 Wilmoth TA, Elder JP. An assessment of research on breastfeeding promotion strategies in developing countries. Soc Sci Med. 1995;41:579-594. [pmid: 7481952].
89 Schlickau JM, Wilson ME. Breastfeeding as health-promoting behaviour for Hispanic women: literature review. J Adv Nurs. 2005;52:200-210. [pmid: 16164481].
90 Heinig MJ, Follett JR, Ishii KD, Kavanagh-Prochaska K, Cohen R, Panchula J. Barriers to compliance with infant-feeding recommendations among low-income women. J Hum Lact. 2006;22:27-38. [pmid: 16467285].
91 Higgins B. Puerto Rican cultural beliefs: influence on infant feeding practices in western New York. J Transcult Nurs. 2000;11:19-30. [pmid: 11982071].
92 Arora S, McJunkin C, Wehrer J, Kuhn P. Major factors influencing breastfeeding rates: mother’s perception of father’s attitude and milk supply. Pediatrics. 2000;106:E67. [pmid: 11061804].
93 Wolfberg AJ, Michels KB, Shields W, O’Campo P, Bronner Y, Bienstock J. Dads as breastfeeding advocates: results from a randomized controlled trial of an educational intervention. Am J Obstet Gynecol. 2004;191:708-712. [pmid: 15467529].
94 Dennis CL. Breastfeeding initiation and duration: a 1990–2000 literature review. J Obstet Gynecol Neonatal Nurs. 2002;31:12-32.
95 Scott JA, Binns CW. Factors associated with the initiation and duration of breastfeeding: a review of the literature. Breastfeeding Rev. 1999;7:5-16.
96 Bar-Yam NB, Darby L. Fathers and breastfeeding: a review of the literature. J Hum Lact. 1997;13:45-50. [pmid: 9233185].
97 Pisacane A, Continisio GI, Aldinucci M, D’Amora S, Continisio P. A controlled trial of the father’s role in breastfeeding promotion. Pediatrics. 2005;116:e494-e498. [pmid: 16199676].
98 Li R, Hsia J, Fridinger F, Hussain A, Benton-Davis S, Grummer-Strawn L. Public beliefs about breastfeeding policies in various settings. J Am Diet Assoc. 2004;104:1162-1168. [pmid: 15215778].
99 Vance MR. Breastfeeding legislation in the United States: a general overview and implications for helping mothers. Leaven. 2005;41:51-54. Available at http://www.llli.org/llleaderweb/LV/LVJunJul05p51.html. Accessed March 10, 2010.
100 McIntyre E, Turnbull D, Hiller JE. Breastfeeding in public places. J Hum Lact. 1999;15:131-135. [pmid: 10578789].
101 Khoury AJ, Moazzem SW, Jarjoura CM, Carothers C, Hinton A. Breast-feeding initiation in low-income women: role of attitudes, support, and perceived control. Womens Health Issues. 2005;15:64-72. [pmid: 15767196].
102 Raisler J. Against the odds: Breastfeeding experiences of low income mothers. J Midwifery Womens Health. 2000;45:253-263. [pmid: 10907335].
103 Hannon PR, Willis SK, Bishop-Townsend V, Martinez IM, Scrimshaw SC. African-American and Latina adolescent mothers’ infant feeding decisions and breastfeeding practices: a qualitative study. J Adolesc Health. 2000;26:399-407. [pmid: 10822181].
104 Brownell K, Hutton L, Hartman J, Dabrow S. Barriers to breastfeeding among African American adolescent mothers. Clin Pediatr (Phila). 2002;41:669-673. [pmid: 12462316].
105 Mitra AK, Khoury AJ, Hinton AW, Carothers C. Predictors of breastfeeding intention among low-income women. Matern Child Health J. 2004;8:65-70. [pmid: 15198173].
106 Daniels MJ, Parrot RL. Prenatal care from the woman’s perspective: a thematic analysis of the newspaper media. Parrot RL, Condit CM, editors. Evaluating women’s health messages: a resource book. Thousand Oaks, CA. Sage. 1996:222-233.
107 Shannon T, O’Donnell MJ, Skinner K. Breastfeeding in the 21st century: overcoming barriers to help women and infants. Nurs Womens Health. 2007;11:568-575. [pmid: 18088294].
108 Frerichs L, Andsager JL, Campo S, Aquilino M, Stewart Dyer C. Framing breastfeeding and formula feeding messages in popular U.S. magazines. Women Health. 2006;44:95-118. [pmid: 17182529].
109 Swanson V, Power K, Kaur B, Carter H, Shepherd K. The impact of knowledge and social influences on adolescents’ breast-feeding beliefs and intentions. Public Health Nutr. 2006;9:297-305. [pmid: 16684380].
110 Blair-Stevens T, Cork S. “Who wants to eat in a toilet?” A social marketing approach to breast-feeding in public places and at work”. J Fam Health Care. 2008;18:167-170. [pmid: 18973089].
111 McIntyre E, Turnbull D, Hiller JE. Suitability of breastfeeding facilities outside the home: an audit of baby change rooms in shopping centres. Breastfeed Rev. 1999;7:17-20. [pmid: 10197367].
112 Li R, Fein SB, Chen J, Grummer-Strawn LM. Why mothers stop breastfeeding: mothers’ self-reported reasons for stopping during the first year. Pediatrics. Oct. 2008;122(Suppl 2):S69-S76. [pmid: 18829834].
113 Gaiva MAM, Medeiros LS. Insufficient lactation: a proposal for action by nurses. Ciencia. 2006;5:255-262.
114 Stuff JE, Nichols BL. Nutrient intake and growth performance of older infants fed human milk. J Pediatr. 1989;115:959-968. [pmid: 2585235].
115 Dewey KG, Heinig J, Nommsen LA, Lonnerdal B. Adequacy of energy intake among breast-fed infants in the DARLING study: relationships to growth velocity, morbidity, and activity levels. J Pediatr. 1991;119:538-547. [pmid: 1919883].
116 Arlotti JP, Cottrell BH, Lee SH, Curtin JJ. Breastfeeding among low-income women with and without peer support. J Community Health Nurs. 1998;15:163-178. [pmid: 9747023].
117 Amir LH. Breastfeeding—managing “supply” difficulties. Aust Fam Physician. 2006;35:686-689. [pmid: 16969436].
118 Butte NF, Garza C, Smith EO, Nichols BL. Human milk intake and growth in exclusively breast-fed infants. J Pediatr. 1984;104:187-195. [pmid: 6694010].
119 Neville MC, Keller R, Seacat J, Lutes V, Neifert M, Casey C, et al. Studies in human lactation: milk volumes in lactating women during the onset of lactation and full lactation. Am J Clin Nutr. 1988;48:1375-1386. [pmid: 3202087].
120 Powers NG. Slow weight gain and low milk supply in the breastfeeding dyad. Clin Perinatol. 1999;26:399-430. [pmid: 10394494].
121 Dykes F, Williams C. Falling by the wayside: a phenomenological exploration of perceived breast-milk inadequacy in lactating women. Midwifery. 1999;15:232-246. [pmid: 11216257].
122 Hailes JF, Wellard SJ. Support for breastfeeding in the first postpartum month: perceptions of breastfeeding women. Breastfeed Rev. 2000;8:5-9. [pmid: 11210281].
123 Hong TM, Callister LC, Schwartz R. First time mothers’ views of breastfeeding support from nurses. MCN Am J Matern Child Nurs. 2003;28:10-15. [pmid: 12514351].
124 Taveras EM, Capra AM, Braveman PA, Jensvold NG, Escobar GJ, Lieu TA. Clinician support and psychosocial risk factors associated with breastfeeding discontinuation. Pediatrics. 2003;112:108-115. [pmid: 12837875].
125 Pletta KH, Eglash A, Choby K. Benefits of breastfeeding: a review for physicians. WMJ. 2000;99:55-58. [pmid: 10843027].
126 Isabella PH, Isabella RA. Correlates of successful breastfeeding: a study of social and personal factors. J Hum Lact. 1994;10:257-264. [pmid: 7619281].
127 Williams EL, Pan E. Breastfeeding initiation among a low income multiethnic population in northern California: an exploratory study. J Hum Lact. 1994;10:245-251. [pmid: 7619279].
128 Lawson K, Tulloch MI. Breastfeeding duration: prenatal intentions and postnatal practices. J Adv Nurs. 1995;22:841-849. [pmid: 8568056].
129 Johnston ML, Esposito N. Barriers and facilitators for breastfeeding among working women in the United States. J Obstet Gynecol Neonatal Nurs. 2007;36:9-20.
130 Hawkins SS, Griffiths LJ, Dezateux C, Law C. Millennium Cohort Study Child Health Group. Maternal employment and breast-feeding initiation: findings from the Millennium Cohort Study. Paediatr Perinat Epidemiol. 2007;21:242-247. [pmid: 17439534].
131 Kimbro RT. On-the-job moms: work and breastfeeding initiation and duration for a sample of low-income women. Matern Child Health J. 2006;10:19-26. [pmid: 16521055].
132 Society for Human Resource Management. 2009. Employee benefits: examining employee benefits in a fiscally challenging economy. Available at: www.shrm.org/Research/SurveyFindings/Articles/Documents/09-0295_Employee_Benefits_Survey_Report_spread_fnl.pdf. Accessed July 21, 2010.
133 Rojjanasrirat W. Working women’s breastfeeding experiences. MCN Am J Matern Child Nurs. 2004;29:222-227. [pmid: 15238746].
134 Miller NH, Miller DJ, Chism M. Breastfeeding practices among resident physicians. Pediatrics. 1996;98:434-437. [pmid: 8784369].
135 Stevens KV, Janke J. Breastfeeding experiences of active duty military women. Mil Med. 2003;168:380-384. [pmid: 12775173].
136 Thompson PE, Bell P. Breast-feeding in the workplace: how to succeed. Issues Comp Pediatr Nurs. 1997;20:1-9.
137 Witters-Green R. Increasing breastfeeding rates in working mothers. Families System Health. 2003;21:415-434.
138 Fein SB, Roe B. The effect of work status on initiation and duration of breast-feeding. Am J Public Health. 1998;88:1042-1046. [pmid: 9663151].
139 Arthur CR, Saenz RB, Replogle WH. The employment-related breastfeeding decisions of physician mothers. J Miss State Med Assoc. 2003;44:383-387. [pmid: 14686000].
140 Roe B, Whittington LA, Fein SB, Teisl MF. Is there competition between breastfeeding and maternal employment?. Demography. 1999;36:157-171. [pmid: 10332608].
141 Brown CA, Poag S, Kasprzycki C. Exploring large employers’ and small employers’ knowledge, attitudes, and practices on breastfeeding support in the workplace. J Hum Lact. 2001;17:39-46. [pmid: 11847850].
142 Scott JA, Landers MC, Hughes RM, Binns CW. Psychosocial factors associated with the abandonment of breastfeeding prior to hospital discharge. J Hum Lact. 2001;17:24-30. [pmid: 11847848].
143 Renfrew MJ, McFadden A, Dykes F, Wallace LM, Abbott S, Burt S, et al. Addressing the learning deficit in breastfeeding: strategies for change. Matern Child Nutr. 2006;2:239-244. [pmid: 16999769].
144 Dewey KG, Nommsen-Rivers LA, Heinig MJ, Cohen RJ. Risk factors for suboptimal infant breastfeeding behavior, delayed onset of lactation, and excess neonatal weight loss. Pediatrics. 2003;112:607-619. [pmid: 12949292].
145 Swenne I, Ewald U, Gustafsson J, Sandberg E, Ostenson CG. Inter-relationship between serum concentrations of glucose, glucagon and insulin during the first two days of life in healthy newborns. Acta Paediatr. 1994;83:915-919. [pmid: 7819685].
146 Bergevin Y, Dougherty C, Kramer MS. Do infant formula samples shorten the duration of breast-feeding?. Lancet. 1983;1:1148-1151. [pmid: 6133166].
147 DiGirolamo AM, Grummer-Strawn LM, Fein S. Maternity care practices: implications for breastfeeding. Birth. 2001;28:94-100. [pmid: 11380380].
148 Murray EK, Ricketts S, Dellaport J. Hospital practices that increase breastfeeding duration: results from a population-based study. Birth. 2007;34:202-211. [pmid: 17718870].
149 Rosenberg KD, Eastham CA, Kasehagen LJ, Sandoval AP. Marketing infant formula through hospitals: the impact of commercial hospital discharge packs on breastfeeding. Am J Public Health. 2008;98:290-295. [pmid: 18172152].
150 Dabrowski GA. Skin-to-skin contact: giving birth back to mothers and babies. Nurs Womens Health. 2007;11:64-71. [pmid: 17883818].
151 Riordan J, Gill-Hopple K, Angeron J. Indicators of effective breastfeeding and estimates of breast milk intake. J Hum Lact. 2005;21:406-412. [pmid: 16280556].
152 DiGirolamo AM, Grummer-Strawn LM, Fein SB. Effect of maternity-care practices on breastfeeding. Pediatrics. Oct. 2008;122(Suppl 2):S43-S49. [pmid: 18829830].
153 Rowe-Murray HJ, Fisher JR. Baby-friendly hospital practices: cesarean section is a persistent barrier to early initiation of breastfeeding. Birth. 2002;29:124-131. [pmid: 12000413].
154 Pérez-Escamilla R, Maulěn-Radovan I, Dewey KG. The association between cesarean delivery and breast-feeding outcomes among Mexican women. Am J Public Health. 1996;86:832-836. [pmid: 8659658].
155 Rajan L. The impact of obstetric procedures and analgesia/anaesthesia during labour and delivery on breast feeding. Midwifery. 1994;10:87-103. [pmid: 8057961].
156 Leung GM, Lam TH, Ho LM. Breast-feeding and its relation to smoking and mode of delivery. Obstet Gynecol. 2002;99:785-794. [pmid: 11978288].
157 Pechlivani F, Vassilakou T, Sarafidou J, Zachou T, Anastasiou CA, Sidossis LS. Prevalence and determinants of exclusive breastfeeding during hospital stay in the area of Athens, Greece. Acta Paediatr. 2005;94:928-934. [pmid: 16188817].
158 Menacker F, Hamlton BE. Recent trends in cesarean delivery in the United States NCHS data brief, no 35. Hyattsville, MD. U.S. Department of Health and Human Services, Centers for Disease Control and Prevention. 2010.
159 Hamilton BE, Martin JA, Ventura SJ. Births: preliminary data for 2007. National Vital Statistics Reports. 2009;57(12):1-23. Available at: http://www.cdc.gov/nchs/data/nvsr/nvsr57/nvsr57_12.pdf. Accessed July 8, 2010.
160 Szucs KA, Miracle DJ, Rosenman MB. Breastfeeding knowledge, attitudes, and practices among providers in a medical home. Breastfeed Med. 2009;4:31-42. [pmid: 19196036].
161 Taveras EM, Li R, Grummer-Strawn L, Richardson M, Marshall R, Rêgo VH, et al. Opinions and practices of clinicians associated with continuation of exclusive breastfeeding. Pediatrics. 2004;113:e283-e290. [pmid: 15060254].
162 Feldman-Winter LB, Schanler RJ, O’Connor KG, Lawrence RA. Pediatricians and the promotion and support of breastfeeding. Arch Pediatr Adolesc Med. 2008;162:1142-1149. [pmid: 19047541].
163 Wallace LM, Kosmala-Anderson J. A training needs survey of doctors’ breastfeeding support skills in England. Matern Child Nutr. 2006;2:217-231. [pmid: 16999767].
164 Freed GL, Clark SJ, Sorenson J, Lohr JA, Cefalo R, Curtis P. National assessment of physicians’ breast-feeding knowledge, attitudes, training, and experience. JAMA. 1995;273:472-476. [pmid: 7837365].
165 Schanler RJ, O’Connor KG, Lawrence RA. Pediatricians’ practices and attitudes regarding breastfeeding promotion. Pediatrics. 1999;103:E35. [pmid: 10049991].
166 DiGirolamo A, Thompson N, Martorell R, Fein S, Grummer-Strawn L. Intention or experience? Predictors of continued breastfeeding. Health Educ Behav. 2005;32:208-226. [pmid: 15749967].
167 Anderson AS, Guthrie CA, Alder EM, Forsyth S, Howie PW, Williams FL. Rattling the plate—reasons and rationales for early weaning. Health Educ Res. 2001;16:471-479. [pmid: 11525393].
168 U.S. Preventive Services Task Force. Primary care interventions to promote breastfeeding: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2008;149:560-564. [pmid: 18936503].
169 Grassley J, Eschiti V. Grandmother breastfeeding support: what do mothers need and want?. Birth. 2008;35:329-335. [pmid: 19036046].
170 US Department of Labor, Bureau of Labor Statistics. Table 6. Employment status of mothers with own children under 3 years old by single year of age of youngest child and marital status, 2008–09 annual averages. 2010. Available at: http://www.bls.gov/news.release/famee.t06.htm. Accessed July 20, 2010.
171 Olson BH, Haider SJ, Vangjel L, Bolton TA, Gold JG. A quasi-experimental evaluation of a breastfeeding support program for low income women in Michigan. Matern Child Health J. 2010;14:86-93. [pmid: 19082697].
172 Yun S, Liu Q, Mertzlufft K, Kruse C, White M, Fuller P, et al. Evaluation of the Missouri WIC (Special Supplemental Nutrition Program for Women, Infants, and Children) breast-feeding peer counselling programme. Public Health Nutr. 2010;13:229-237. [pmid: 19607746].
173 Anderson AK, Damio G, Young S, Chapman DJ, Pérez-Escamilla R. A randomized trial assessing the efficacy of peer counseling on exclusive breastfeeding in a predominantly Latina low-income community. Arch Pediatr Adolesc Med. 2005;159:836-841. [pmid: 16143742].
174 Chapman DJ, Damio G, Young S, Pérez-Escamilla R. Effectiveness of breastfeeding peer counseling in a lowincome, predominantly Latina population: a randomized controlled trial. Arch Pediatr Adolesc Med. 2004;158:897-902. [pmid: 15351756].
175 U.S. Department of Agriculture. Food and Nutrition Service. Fathers supporting breastfeeding. Available at: http://www.fns.usda.gov/wic/fathers/supportingbreastfeeding.htm. Accessed July 9, 2010.
176 Stremler J, Lovera D. Insight from a breastfeeding peer support pilot program for husbands and fathers of Texas WIC participants. J Hum Lact. 2004;20:417-422. [pmid: 15479662].
177 Ingram J, Johnson D. A feasibility study of an intervention to enhance family support for breast feeding in a deprived area in Bristol, UK. Midwifery. 2004;20:367-379. [pmid: 15571885].
178 Bentley ME, Caulfield LE, Gross SM, Bronner Y, Jensen J, Kessler LA, et al. Sources of influence on intention to breastfeed among African-American women at entry to WIC. J Hum Lact. 1999;15:27-34. [pmid: 10578772].
179 Grassley JS, Nelms TP. The breast-feeding conversation: a philosophic exploration of support. ANS Adv Nurs Sci. 2008;31:E55-E66. [pmid: 19033740].
180 U.S. Department of Agriculture, Food and Nutrition Service. Benefits and services: breastfeeding promotion and support in WIC. Available at: http://www.fns.usda.gov/wic/Breastfeeding/breastfeedingmainpage.htm. Accessed July 9, 2010.
181 Every Mother, Inc. Using Loving Support to grow and glow in WIC: breastfeeding training for local WIC staff. 2007. Available at: http://everymother.org/training_programs.php. Accessed July 9, 2010.
182 U.S. Department of Agriculture, Food and Nutrition Service. Loving Support makes breastfeeding work. Available at: http://www.nal.usda.gov/wicworks/Learning_Center/loving_support.html. Accessed July 9, 2010.
183 U.S. Department of Agriculture. Breastfeeding: a magical bond of love. Available at: http://www.nal.usda.gov/wicworks/Learning_Center/support_bond.html. Accessed July 9, 2010.
184 Patient Protection and Affordable Care Act of 2010, H.R. 3590, 111th Cong., 2nd Sess. 2010. Available at: http://democrats.senate.gov/reform/patient-protectionaffordable-care-act-as-passed.pdf. Accessed July 20, 2010.
185 Chamberlain LB, Merewood A, Malone KL, Cimo S, Philipp BL. Calls to an inner-city hospital breastfeeding telephone support line. J Hum Lact. 2005;21:53-88. [pmid: 15681637].
186 Parrilla-Rodríguez AM, Dávila Torres R, Gorrín-Peralta JJ. Profile of calls to a breastfeeding clinic information and help telephone line. P R Health Sci J. 2001;20:377-381. [pmid: 11845670].
187 Cramton R, Zain-Ul-Abideen M, Whalen B. Optimizing successful breastfeeding in the newborn. Curr Opin Pediatr. 2009;21:386-396. [pmid: 19421060].
188 Dennis CL, Kingston D. A systematic review of telephone support for women during pregnancy and the early postpartum period. J Obstet Gynecol Neonatal Nurs. 2008;37:301-314.
189 Britton C, McCormick FM, Renfrew MJ, Wade A, King SE. Support for breastfeeding mothers. Cochrane Database Syst Rev. 2007(1):CD001141.
190 Morrow AL, Guerrero ML, Shults J, Calva JJ, Lutter C, Bravo J, et al. Efficacy of home-based peer counselling to promote exclusive breastfeeding: a randomised controlled trial. Lancet. 1999;353:1226-1231. [pmid: 10217083].
191 Chapman DJ, Morel K, Anderson AK, Damio G, Pérez-Escamilla R. Breastfeeding peer counseling: from efficacy through scale-up. J Hum Lact. 2010;26:314-326. [pmid: 20715336].
192 Bronner Y, Barber T, Miele L. Breastfeeding peer counseling: rationale for the National WIC Survey. J Hum Lact. 2001;17:135-139. [pmid: 11847827].
193 U.S. Department of Agriculture, Food and Nutrition Service. Using Loving Support to implement best practices in peer counseling. Available at: http://www.nal.usda.gov/wicworks/Learning_Center/support_peer.html. July 9, 2010.
194 Hopkinson J, Gallagher MK. Assignment to a hospital-based breastfeeding clinic and exclusive breastfeeding among immigrant Hispanic mothers: a randomized, controlled trial. J Hum Lact. 2009;25:287-296. [pmid: 19436060].
195 Howard C, Howard F, Lawrence R, Andresen E, DeBlieck E, Weitzman M. Office prenatal formula advertising and its effect on breast-feeding patterns. Obstet Gynecol. 2000;95:296-303. [pmid: 10674597].
196 Dungy CI, Christensen-Szalanski J, Losch M, Russell D. Effect of discharge samples on duration of breast-feeding. Pediatrics. 1992;90:233-237. [pmid: 1641288].
197 Howard CR, Howard FM, Weitzman M, Lawrence R. Antenatal formula advertising: another potential threat to breast-feeding. Pediatrics. 1994;94:102-104. [pmid: 7710482].
198 Donnelly A, Snowden HM, Renfrew MJ, Woolridge MW. Commercial hospital discharge packs for breastfeeding women. Cochrane Database Syst Rev. 2000(2):CD002075.
199 BusinessWire. Mead Johnson, maker of Enfamil, loses multi-million dollar false advertising case against store-brand infant formulas. Press release; December 2, 2009. Available at: http://www.businesswire.com/portal/site/home/permalink/?ndmViewId=news_view&newsId=20091202006020&newsLang=en. Accessed July 9, 2010.
200 Social Marketing Institute. Success stories: national WIC breastfeeding promotion project. Available at: http://www.social-marketing.org/success/cs-nationalwic.html. Accessed July 9, 2010.
201 U.S. Department of Health and Human Services, Office on Women’s Health. National breastfeeding awareness campaign results: babies were born to be breastfed [presentation]. 2009. Available at: http://www.womenshealth.gov/breastfeeding/government-programs/national-breastfeeding-campaign/results/campaign_results.ppt. August 4, 2010.
202 Fox S, Jones S. The social life of health information: Americans’ pursuit of health takes place within a widening network of both online and offline services. Available at: http://www.pewinternet.org/~/media//Files/Reports/2009/PIP_Health_2009.pdf. Accessed July 27, 2010.
203 American Academy of Pediatrics, American College of Obstetricians and Gynecologists. Guidelines for perinatal care. 6th ed. Chicago. American Academy of Pediatrics. 2007.
204 California WIC Association, UC Davis Human Lactation Center. Depends qon where you are born: California hospitals must close the gap in exclusive breastfeeding rates. 2008. Available at: http://www.calwic.org/storage/documents/pk%21/2008/bfhospital2008.pdf. Accessed December 27, 2010.
205 Stark AR, Lannon CM. Systems changes to prevent severe hyperbilirubinemia and promote breastfeeding: pilot approaches. J Perinatol. 2009;29(Suppl 1):S53-S57. [pmid: 19177060].
206 Howard CR, Schaffer SJ, Lawrence RA. Attitudes, practices, and recommendations by obstetricians about infant feeding. Birth. 1997;24:240-246. [pmid: 9460315].
207 DiGirolamo AM, Grummer-Strawn LM, Fein SB. Do perceived attitudes of physicians and hospital staff affect breastfeeding decisions?. Birth. 2003;30:94-100. [pmid: 12752166].
208 Centers for Disease Control and Prevention. National Survey of Maternity Practices in Infant Nutrition and Care. Available at: http://www.cdc.gov/breastfeeding/data/mpinc/index.htm. Accessed July 8, 2010.
209 Bystrova K, Matthiesen AS, Vorontsov I, Widström AM, Ransjö-Arvidson AB, Uvnäs-Moberg K. Maternal axillar and breast temperature after giving birth: effects of delivery ward practices and relation to infant temperature. Birth. 2007;34:291-300. [pmid: 18021144].
210 Fairbank L, O’Meara S, Renfrew MJ, Woolridge M, Sowden AJ, Lister-Sharp D. A systematic review to evaluate the effectiveness of interventions to promote the initiation of breastfeeding. Health Technol Assess. 2000;4(25):1-171. [pmid: 11111103].
211 Pérez-Escamilla R, Segura-Millán S, Pollitt E, Dewey KG. Effect of the maternity ward system on the lactation success of low-income urban Mexican women. Early Hum Dev. 1992;31:25-40. [pmid: 1486816].
212 Kersting M, Dulon M. Assessment of breast-feeding promotion in hospitals and follow-up survey of motherinfant pairs in Germany: the SuSe Study. Public Health Nutr. 2002;5:547-552. [pmid: 12186663].
213 Blomquist HK, Jonsbo F, Serenius F, Persson LA. Supplementary feeding in the maternity ward shortens the duration of breast feeding. Acta Paediatr. 1994;83:1122-1126. [pmid: 7841722].
214 Coutinho SB, de Lira PI, de Carvalho Lima M, Ashworth A. Comparison of the effect of two systems for the promotion of exclusive breastfeeding. Lancet. 2005;366:1094-1100. [pmid: 16182897].
215 Illingworth RS, Stone DG, Jowett GH, Scott JF. Self-demand feeding in a maternity unit. Lancet. 1952;1:683-687. [pmid: 14909523].
216 Vittoz JP, Labarere J, Castell M, Durand M, Pons JC. Effect of a training program for maternity ward professionals on duration of breastfeeding. Birth. 2004;31:302-307. [pmid: 15566343].
217 World Health Organization, United Nation’s Children’s Fund. The Baby-Friendly Hospital Initiative—monitoring and reassessment: tools to sustain progress. Geneva. World Health Organization. 1999.
218 Joint Commission on Accreditation of Healthcare Organizations. Raising the bar with bundles: treating patients with an all-or-nothing standard. Joint Commission perspectives on patient safety. 2006;6(4):5-6.
219 Salem-Schatz S, Peterson LE, Palmer RH, Clanton SM, Ezhuthachan S, Luttrell RC, et al. Barriers to first-week follow-up of newborns: findings from parent and clinician focus groups. Jt Comm J Qual Saf. 2004;30:593-601. [pmid: 15565758].
220 Cherouny PH, Federico FA, Haraden C, Gullo SL, Resar R. Idealized design of perinatal care. IHI Innovation Series white paper. Cambridge, MA. Institute for Healthcare Improvement. 2005. Available at: http://www.ihi.org/IHI/Results/WhitePapers/IdealizedDesignofPerinatalCareWhitePaper.htm. Accessed July 19, 2010.
221 Baby-Friendly USA. The ten steps to successful breastfeeding. Available at: http://www.babyfriendlyusa.org/eng/10steps.html. Accessed July 15, 2010.
222 American Academy of Pediatrics. Safe and healthy beginnings: a resource toolkit for hospitals and physicians’ offices. Elk Grove Village, IL. American Academy of Pediatrics. 2008. Available at: http://practice.aap.org/content.aspx?aid=2577. Accessed July 19, 2010.
223 Merewood A, Philipp BL. Peer counselors for breastfeeding mothers in the hospital setting: trials, training, tributes, and tribulations. J Hum Lact. 2003;19:72-76. [pmid: 12587648].
224 Mickens AD, Modeste N, Montgomery S, Taylor M. Peer support and breastfeeding intentions among black WIC participants. J Hum Lact. 2009;25:157-162. [pmid: 19414821].
225 Brown A, Raynor P, Lee M. Young mothers who choose to breast feed: the importance of being part of a supportive breast-feeding community. Midwifery. 2009. Nov 4. [Epub ahead of print].
226 Philipp BL, Merewood A, Gerendas EJ, Bauchner H. Breastfeeding information in pediatric textbooks needs improvement. J Hum Lact. 2004;20:206-210. [pmid: 15117520].
227 International Board of Lactation Consultant Examiners. Required education and experience. 2009. Available at: http://americas.iblce.org/required-education-and-experience. Accessed July 27, 2010.
228 Bonuck KA, Trombley M, Freeman K, McKee D. Randomized, controlled trial of a prenatal and postnatal lactation consultant intervention on duration and intensity of breastfeeding up to 12 months. Pediatrics. 2005;116:1413-1426. [pmid: 16322166].
229 Castrucci BC, Hoover KL, Lim S, Maus KC. A comparison of breastfeeding rates in an urban birth cohort among women delivering infants at hospitals that employ and do not employ lactation consultants. J Public Health Manag Pract. 2006;12:578-585. [pmid: 17041307].
230 Dweck N, Augustine M, Pandya D, Valdes-Greene R, Visintainer P, Brumberg HL. NICU lactation consultant increases percentage of outborn versus inborn babies receiving human milk. J Perinatol. 2008;28:136-140. [pmid: 18094704].
231 Centers for Disease Control and Prevention. Breastfeeding Report Card—United States, 2009. Available at: http://www.cdc.gov/Features/BreastFeedingData/. Accessed August 3, 2010.
232 Mannel R, Mannel RS. Staffing for hospital lactation programs: recommendations from a tertiary care teaching hospital. J Hum Lact. 2006;22:409-417. [pmid: 17062786].
233 Thurman SE, Allen PJ. Integrating lactation consultants into primary health care services: are lactation consultants affecting breastfeeding success?. Pediatr Nurs. 2008;34:419-425. [pmid: 19051846].
234 Martin JA, Hamilton BE, Sutton PD, Ventura SJ, Menacker F, Kirmeyer S, et al. Births: final data for 2006. National Vital Stat Rep. 2009;57(7):1-102.
235 Chatterton RT Jr, Hill PD, Aldag JC, Hodges KR, Belknap SM, Zinaman MJ. Relation of plasma oxytocin and prolactin concentrations to milk production in mothers of preterm infants: influence of stress. J Clin Endocrinol Metab. 2000;85:3661-3668. [pmid: 11061519].
236 Hill PD, Aldag JC, Chatterton RT. Initiation and frequency of expressing and milk production in mothers of non-nursing preterm infants. J Hum Lact. 2001;17:9-13. [pmid: 11847858].
237 Boyd CA, Quigley MA, Brocklehurst P. Donor breast milk versus infant formula for preterm infants: systematic review and meta-analysis. Arch Dis Child Fetal Neonatal Ed. 2007;92:F169-F175. [pmid: 16556615].
238 Lucas A, Cole TJ. Breast milk and neonatal necrotising enterocolitis. Lancet. 1990;336:1519-1523. [pmid: 1979363].
239 McGuire W, Anthony MY. Donor human milk versus formula for preventing necrotising enterocolitis in preterm infants: systematic review. Arch Dis Child Fetal Neonatal Ed. 2003;88:F11-F14. [pmid: 12496220].
240 Schanler RJ, Shulman RJ, Lau C. Feeding strategies for premature infants: beneficial outcomes of feeding fortified human milk versus preterm formula. Pediatrics. 1999;103:1150-1157. [pmid: 10353922].
241 Schanler RJ, Lau C, Hurst NM, Smith EO. Randomized trial of donor human milk versus preterm formula as substitutes for mothers’ own milk in the feeding of extremely premature infants. Pediatrics. 2005;116:400-406. [pmid: 16061595].
242 Grave GD, Nelson SA, Walker WA, Moss RL, Dvorak B, Hamilton FA, et al. New therapies and preventive approaches for necrotizing enterocolitis: report of a research planning workshop. Pediatr Res. 2007;62:510-514. [pmid: 17667844].
243 Blakely ML, Gupta H, Lally KP. Surgical management of necrotizing enterocolitis and isolated intestinal perforation in premature neonates. Semin Perinatol. 2008;32:122-126. [pmid: 18346536].
244 Abdullah F, Zhang Y, Camp M, Mukherjee D, Gabre-Kidan A, Colombani PM, et al. Necrotizing enterocolitis in 20,822 infants: analysis of medical and surgical treatments. Clin Pediatr. 2010;49:166-171.
245 Bisquera JA, Cooper TR, Berseth CL. Impact of necrotizing enterocolitis on length of stay and hospital charges in very low birth weight infants. Pediatrics. 2002;109:423-428. [pmid: 11875136].
246 Arnold LD. The cost-effectiveness of using banked donor milk in the neonatal intensive care unit: prevention of necrotizing enterocolitis. J Hum Lact. 2002;18:172-177. [pmid: 12033080].
247 Human Milk Banking Association of North America. From the president. HMBANA Matters. 2009;6(2).
248 Arnold LD. Human milk in the NICU: policy into practice. Sudbury, MA. Jones and Bartlett Publishers. 2010.
249 Human Milk Banking Association of North America. 2009. Guidelines for the establishment and operation of a donor human milk bank. Raleigh, NC. Human Milk Banking Association of North America. 2009.
250 Human Milk Banking Association of North America. How much is enough?. HMBANA Matters. March. 2008;5(7).
251 Arnold LD. The ethics of donor human milk banking. Breastfeed Med. 2006;1:3-13. [pmid: 17661555].
252 Arnold LD. U.S. health policy and access to banked donor human milk. Breastfeed Med. 2008;3:221-229. [pmid: 19086825].
253 US Department of Labor, Bureau of Labor Statistics. Table 1. Employment status of the civilian noninstitutional population by age and sex, 2004 annual averages. Women in the labor force: a databook; 2005. Report 985. Available at: http://www.bls.gov/cps/wlf-databook2005.htm. Accessed July 20, 2010.
254 Johnson TD. Maternity leave and employment patterns of first time mothers: 1961–2003, Current Population Report. Washington, DC. U.S. Census Bureau. 2008:70-113.
255 Flanagan K, West J. Children born in 2001: first results from the base year of the Early Childhood Longitudinal Study, Birth Cohort (ECLS–B) (NCES 2005–036. Washington, DC. National Center for Education Statistics. 2004. Available at: http://www.childcareresearch.org/location/ccrca4623. Accessed July 27, 2010.
256 US Child Care Bureau Child care and development fund (CCDF): report to Congress. Washington, DC. U.S. Department of Health and Human Services, Administration for Children and Families. 2003. Available at: http://www.acf.hhs.gov/programs/ccb/ccdf/rtc/rtc2001/CCDFreport.pdf. Accessed July 20, 2010.
257 Chatterji P, Frick KD. Does returning to work after childbirth affect breastfeeding practices?. Rev Econ Househ. 2005;3:315-335.
258 Li R, Darling N, Maurice E, Barker L, Grummer-Strawn LM. Breastfeeding rates in the United States by characteristics of the child, mother, or family: the 2002 National Immunization Survey. Pediatrics. 2005;115:e31-e37. [pmid: 15579667].
259 Mandal B, Roe BE, Fein SB. The differential effects of full-time and part-time work status on breastfeeding. Health Policy. 2010;97:79-86. [pmid: 20400199].
260 Gielen AC, Faden RR, O’Campo P, Brown CH, Paige DM. Maternal employment during the early postpartum period: effects on initiation and continuation of breastfeeding. Pediatrics. 1991;87:298-305. [pmid: 2000269].
261 Kurinij N, Shiono PH, Ezrine SF, Rhoads GG. Does maternal employment affect breast-feeding?. Am J Public Health. 1989;79:1247-1250. [pmid: 2764202].
262 Lindberg LD. Trends in the relationship between breastfeeding and postpartum employment in the United States. Soc Biol. 1996;43:191-202. [pmid: 9204696].
263 Lindberg LD. Women’s decisions about breastfeeding and maternal employment. J Marriage Fam. 1996;58:239-251.
264 Ryan AS, Zhou WJ, Arensberg MB. The effect of employment status on breastfeeding in the United States. Womens Health Issues. 2006;16:243-251. [pmid: 17055377].
265 Visness CM, Kennedy KI. Maternal employment and breastfeeding: findings from the 1988 National Maternal and Infant Health Survey. Am J Public Health. 1997;87:945-950. [pmid: 9224174].
266 Berger LM, Hill J, Waldfogel J. Maternity leave, early maternal employment and child health and development in the U.S. Econ J. 2005;115:F29-F47.
267 Whaley SE, Meehan K, Lange L, Slusser W, Jenks E. Predictors of breastfeeding duration for employees of the Special Supplemental Nutrition Program for Women, Infants, and Children (WIC). J Am Diet Assoc. 2002;102:1290-1293. [pmid: 12792629].
268 Cohen R, Mrtek MB. The impact of two corporate lactation programs on the incidence and duration of breast-feeding by employed mothers. Am J Health Promot. 1994;8:436-441. [pmid: 10147273].
269 Smillie CM. Baby-led breastfeeding: a neurobehavioral model for understanding how infants learn to feed [presentation]. HealthConnectOne conference: Birth, Breastfeeding and Beyond. Chicago, IL. September 24, 2009.
270 Perez A, Petersen S. Meeting the needs of the youngest infants in child care. Zero to Three. 2009;29:13-17.
271 Heymann J, Earle A, Hayes J. The Work, Family, and Equity Index: how does the United States measure up?. Montreal, Canada. Project on Global Working Families. Available at: http://www.mcgill.ca/files/ihsp/WFEI2007.pdf. Accessed July 19, 2010.
272 International Labor Organization. R191 maternity protection recommendation, 2000. Available at: http://www.ilo.org/ilolex/cgi-lex/convde.pl?R191. Accessed July 27, 2010.
273 European Commission. Commission improves work-life balance for millions with longer and better maternity leave. October 3. 2008. Available at: www.europa.eu/rapid/pressReleasesAction.do?reference=IP/08/1450&format=HTML&aged=0&language=EN&guiLanguage=en. Accessed August 3, 2010.
274 Service Canada. Employment Insurance (EI) and maternity, parental and sickness benefits. Available at: www.servicecanada.gc.ca/eng/ei/types/special.shtml. Accessed July 27, 2010.
275 US Department of Labor, Bureau of Labor Statistics. National compensation survey: employee benefits in private industry in the United States, March 2007. Available at: http://www.bls.gov/ncs/ebs/sp/ebsm0006.pdf. Accessed August 20, 2010.
276 National Conference of State Legislatures. State pregnancy, childbirth, and adoption leave statutes. Washington, DC. National Conference of State Legislatures. 2009. Available at: http://www.ncsl.org/default.aspx?tabid=13311. Accessed July 20, 2010.
277 Progressive States Network. Maternity/paternity leave (paid family leave). Available at: http://www.progressivestates.org/content/369/maternity-andpaternity-leave. Accessed July 20, 2010.
278 Calnen G. Paid maternity leave and its impact on breastfeeding in the United States: an historic, economic, political, and social perspective. Breastfeed Med. 2007;2(1):34-44. [pmid: 17661618].
279 Health Resources and Services Administration. The business case for breastfeeding: steps for creating a breastfeeding friendly worksite: bottom line benefits. Rockville, MD. U.S. Department of Health and Human Services, Health Resources and Services Administration. 2008. Available at: http://www.ask.hrsa.gov/detail_materials.cfm?ProdID=4135&ReferringID=4121. Accessed July 20, 2010.
280 Cattaneo A, Yngve A, Koletzko B, Guzman LR. Promotion of Breastfeeding in Europe project. Protection, promotion and support of breast-feeding in Europe: current situation. Public Health Nutr. 2005;8(1):39-46. [pmid: 15705244].
281 American Academy of Pediatrics, American Public Health Association, National Resource Center for Health and Safety in Child Care and Early Education. Caring for our children: national health and safety performance standards: guidelines for out-of-home child care programs. 2nd ed. Elk Grove Village, IL. American Academy of Pediatrics. Washington, DC. American Public Health Association. 2002. Available at: http://nrckids.org. Accessed July 20, 2010.
282 American Academy of Pediatrics, American Public Health Association, National Resource Center for Health and Safety in Child Care and Early Education. Preventing childhood obesity in early care and education: selected standards from caring for our children: national health and safety performance standards: guidelines for early care and education programs. 3rd ed. Elk Grove Village, IL. American Academy of Pediatrics. Washington, DC. American Public Health Association. 2010. Available at: http://nrckids.org/CFOC3/PDFVersion/preventing_obesity.pdf. Accessed September 3, 2010.
283 Benjamin SE, Taveras EM, Cradock AL, Walker EM, Slining MM, Gillman MW. State and regional variation in regulations related to feeding infants in child care. Pediatrics. 2009;124:e104-e111. [pmid: 19564255].
284 InfaNET Nutrition for Child Care Providers. Infant, parent, provider, nutrition: building blocks for healthy infants. Available at: http://www.infanet.cahs.colostate.edu/breastmilk.htm. Accessed July 20, 2010.
285 Wisconsin Department of Health and Family Services, Division of Public Health; Wisconsin Breastfeeding Coalition. Taking care of breastfed babies—for childcare centers. 2009. Available at: http://dhs.wisconsin.gov/health/Nutrition/Breastfeeding/BF_FriendlyComm/TakingCareofBreastfedBabies.pdf. Accessed July 20, 2010.
286 Wisconsin Department of Health and Family Services. Promotion and support materials: breastfeeding mothers in childcare centers. Available at: http://www.dhs.wisconsin.gov/health/Nutrition/Breastfeeding/bfpromosupp.htm. Accessed August 4, 2010.
287 Clark A, Anderson J, Adams E, Baker S. Assessing the knowledge, attitudes, behaviors and training needs related to infant feeding, specifically breastfeeding, of child care providers. Matern Child Health J. 2008;12:128-135. [pmid: 17557200].
288 Kramer MS, Matush L, Bogdanovich N, Aboud F, Mazer B, Fombonne E, et al. Health and development outcomes in 6.5-y-old children breastfed exclusively for 3 or 6 mo. Am J Clin Nutr. 2009;90:1070-1074. [pmid: 19710187].
289 Kramer MS, Matush L, Vanilovich I, Platt R, Bogdanovich N, Sevkovskaya Z, et al. Promotion of Breastfeeding Intervention Trial (PROBIT) Study Group. Effect of prolonged and exclusive breast feeding on risk of allergy and asthma: cluster randomised trial. BMJ. 2007;335:815. [pmid: 17855282].
290 Centers for Disease Control and Prevention. Breastfeeding: data and statistics. Available at: http://www.cdc.gov/breastfeeding/data/index.htm. Accessed July 8, 2010.
291 Chapman DJ, Pérez-Escamilla R. US national breastfeeding monitoring and surveillance: current status and recommendations. J Hum Lact. 2009;25:139-150. [pmid: 19286840].
292 Merewood A, Brooks D, Bauchner H, MacAuley L, Mehta SD. Maternal birthplace and breastfeeding initiation among term and preterm infants: a statewide assessment for Massachusetts. Pediatrics. 2006;118:e1048-e1054. [pmid: 17015498].
293 Centers for Disease Control and Prevention. National Immunization Survey. Available at: http://www.cdc.gov/nis/. Accessed July 2, 2010.
294 Centers for Disease Control and Prevention. Pregnancy Risk Assessment Monitoring System (PRAMS). Available at: http://www.cdc.gov/PRAMS/. Accessed November 1, 2010.
295 Centers for Disease Control and Prevention. Pediatric and Pregnancy Nutrition Surveillance System. Available at: http://www.cdc.gov/pednss/. Accessed July 2, 2010.
296 Chapman DJ, Merewood A, Armah RA, Pérez-Escamilla R. Breastfeeding status on U.S. birth certificates: where do we go from here?. Pediatrics. 2008;122:e1159-e1163. [pmid: 19047217].
297 U.S. Department of Health and Human Services. HealthyPeople.gov. Available at: http://www.healthypeople.gov/2020/default.aspx. Accessed January 3, 2011.
298 United States Breastfeeding Committee. Breastfeeding in the United States: a national agenda. Rockville, MD. US Department of Health and Human Services, Health Resources and Services Administration, Maternal and Child Health Bureau. 2001. Available at: http://www.usbreastfeeding.org/LinkClick.aspx?link=Publications%2fNational-Agenda-2001-USBC.pdf&tabid=70&mid=388. Accessed July 27, 2010.