# Message from the Secretary, U.S. Department of Health and Human Services

As one of the most universal and natural facets of motherhood, the ability to breastfeed is a great gift. Breastfeeding helps mothers and babies bond, and it is vitally important to mothers’ and infants’ health.

For much of the last century, America’s mothers were given poor advice and were discouraged from breastfeeding, to the point that breastfeeding became an unusual choice in this country. However, in recent decades, as mothers, their families, and health professionals have realized the importance of breastfeeding, the desire of mothers to breastfeed has soared. More and more mothers are breastfeeding every year. In fact, three-quarters of all newborns in America now begin their lives breastfeeding, and breastfeeding has regained its rightful place in our nation as the norm—the way most mothers feed their newborns.

Each mother’s decision about how she feeds her baby is a personal one. Because of the ramifications of her decision on her baby’s health as well as her own, every mother in our nation deserves information, guidance, and support with this decision from her family and friends, the community where she lives, the health professionals on whom she relies, and her employer.

That is why this Surgeon General’s Call to Action is so important.

This Call to Action describes specific steps people can take to participate in a society-wide approach to support mothers and babies who are breastfeeding. This approach will increase the public health impact of everyone’s efforts, reduce inequities in the quality of health care that mothers and babies receive, and improve the support that families receive in employment and community settings.

I recall my own cherished memories of breastfeeding, and I am grateful for the help and support I received, especially when I went back to work as a young mother. I am also aware that many other mothers are not able to benefit from the support I had. As Secretary of the Department of Health and Human Services, I urge all Americans to be supportive of breastfeeding mothers and families in their communities and to extend their support so that these mothers get the health care, the help, and the encouragement they deserve.

Kathleen Sebelius

Secretary

U.S. Department of Health and Human Services