# Abbreviations and Acronyms

AAP: American Academy of Pediatrics
AHRQ: Agency for Healthcare Research and Quality
CDC: Centers for Disease Control and Prevention
CMS: Centers for Medicare & Medicaid Services
DOL: U.S. Department of Labor
EU: European Union
FDA: U.S. Food and Drug Administration
GAO: Government Accountability Office
HHS: U.S. Department of Health and Human Services
HMBANA: Human Milk Banking Association of North America
HRSA: Health Resources and Services Administration
IBCLC: International Board Certified Lactation Consultant
IBLCE: International Board of Lactation Consultant Examiners
ILO: International Labor Organization
MCHB: Maternal and Child Health Bureau
mPINC: Maternity Practices in Infant Nutrition and Care
NEC: necrotizing enterocolitis
NIH: National Institutes of Health
NIS: National Immunization Survey
OWH: Office on Women’s Health
UNICEF: United Nations Children's Fund
USBC: United States Breastfeeding Committee
USDA: U.S. Department of Agriculture
USPSTF: U.S. Preventive Services Task Force
WHO: World Health Organization
WIC: Special Supplemental Nutrition Program for Women, Infants, and Children