# Excess Health Risks Associated with Not Breastfeeding

Outcome | Excess Risk^*^ (%)(95% CI^†^) | Comparison Groups
Among full-term infants
Acute ear infections (otitis media)2 | 100 (56, 233) | EFF^‡^ vs. EBF^§^ for 3 or 6 mos
Eczema (atopic dermatitis)11 | 47 (14, 92) | EBF <3 mos vs. EBF ≥3 mos
Diarrhea and vomiting (gastrointestinal infection)3 | 178 (144, 213) | Never BF^¶^ vs. ever BF
Hospitalization for lower respiratory tract diseases in the first year4 | 257 (85, 614) | Never BF vs. EBF ≥4 mos
Asthma, with family history2 | 67 (22, 133) | BF <3 mos vs. ≥3 mos
Asthma, no family history2 | 35 (9, 67) | BF <3 mos vs. ≥3 mos
Childhood obesity7 | 32 (16, 49) | Never BF vs. ever BF
Type 2 diabetes mellitus6 | 64 (18, 127) | Never BF vs. ever BF
Acute lymphocytic leukemia2 | 23 (10, 41) | Never BF vs. >6 mos
Acute myelogenous leukemia5 | 18 (2, 37) | Never BF vs. >6 mos
Sudden infant death syndrome2 | 56 (23, 96) | Never BF vs. ever BF
Among preterm infants
Necrotizing enterocolitis2 | 138 (22, 2400) | Never BF vs. ever BF
Among mothers
Breast cancer8 | 4 (3, 6) | Never BF vs. ever BF (per year of breastfeeding)
Ovarian cancer2 | 27 (10, 47) | Never BF vs. ever BF

* The excess risk is approximated by using the odds ratios reported in the referenced studies.

† CI = confidence interval.

‡ EFF = exclusive formula feeding.

§ EBF = exclusive breastfeeding.

¶ BF = breastfeeding.