# Actions to Improve Breastfeeding

## Mothers and Their Families

Action 1 Give mothers the support they need to breastfeed their babies

Implementation Strategies | Potential Actors
Help pregnant women to learn about the importance of breastfeeding for their babies and themselves. | Women Family members and friends Clinicians
Teach mothers to breastfeed. | Women Family members and friends Clinicians
Encourage mothers to talk to their maternity care providers about plans to breastfeed. | Women Family members and friends Clinicians
Support mothers to have time and flexibility to breastfeed. | Women Family members and friends Clinicians
Encourage mothers to ask for help with breastfeeding when needed. | Women Family members and friends Clinicians

Action 2 Develop programs to educate fathers and grandmothers about breastfeeding

Implementation Strategies | Potential Actors
Launch or establish campaigns for breastfeeding education that target a mother’s primary support network, including fathers and grandmothers. | Public health entities Community organizations
Offer classes on breastfeeding that are convenient for family members to attend. | Community organizations Hospitals

## Communities

Action 3 Strengthen programs that provide mother-to-mother support and peer counseling

Implementation Strategies | Potential Actors
Create and maintain a sustainable infrastructure for mother-to-mother support groups and for peer counseling programs in hospitals and community health care settings. | Public health entities Community organizations
Establish peer counseling as a core service available to all women in WIC.^*^ | Federal, state, and local WIC programs

* WIC = Special Supplemental Nutrition Program for Women, Infants, and Children; U.S. Department of Agriculture.

Action 4 Use community-based organizations to promote and support breastfeeding

Implementation Strategies | Potential Actors
Support and fund small nonprofit organizations that promote breastfeeding in communities of color. | Federal, state, and local governments Foundations
Integrate education and support for breastfeeding into public health programs that serve new families. | Public health entities Community organizations
Ensure around-the-clock access to resources that provide assistance with breastfeeding. | Public health entities Community organizations

Action 5 Create a national campaign to promote breastfeeding

Implementation Strategies | Potential Actors
Develop and implement a national public health campaign on breastfeeding that relies heavily on social marketing. | Federal, state, and local partners
Use a variety of media venues to reach young women and their families. | Public health entities Community organizations

Action 6 Ensure that the marketing of infant formula is conducted in a way that minimizes its negative impacts on exclusive breastfeeding

Implementation Strategies | Potential Actors
Hold marketers of infant formula accountable for complying with the International Code of Marketing of Breast-milk Substitutes. | Public health entities Infant formula manufacturers
Take steps to ensure that claims about formula are truthful and not misleading. | HHS/FDA^†^ Federal Trade Commission
Ensure that health care clinicians do not serve as advertisers for infant formula. | Health care professionals

† HHS/FDA = U.S. Department of Health and Human Services/U.S. Food and Drug Administration.

## Health Care

Action 7 Ensure that maternity care practices throughout the United States are fully supportive of breastfeeding

Implementation Strategies | Potential Actors
Accelerate implementation of the Baby-Friendly Hospital Initiative. | Public health entities
Establish transparent, accountable public reporting of maternity care practices in the United States. | HHS/CDC^*^ The Joint Commission
Establish a new advanced certification program for perinatal patient care. | Public health entities The Joint Commission
Establish systems to control the distribution of infant formula in hospitals and ambulatory care facilities. | Hospitals Ambulatory care facilities

* HHS/CDC = U.S. Department of Health and Human Services/Centers for Disease Control and Prevention.

Action 8 Develop systems to guarantee continuity of skilled support for lactation between hospitals and health care settings in the community

Implementation Strategies | Potential Actors
Create comprehensive statewide networks for home- or clinic-based follow-up care to be provided to every newborn in the state. | Public health entities Community organizations
Establish partnerships for integrated and continuous follow-up care after discharge from the hospital. | Hospitals Health care systems Primary care clinicians Community organizations
Establish and implement policies and programs to ensure that participants in WIC^†^ have services in place before discharge from the hospital. | Federal, state, and local WIC programs Hospitals Primary care clinicians Community organizations

† WIC = Special Supplemental Nutrition Program for Women, Infants, and Children; U.S. Department of Agriculture.

Action 9 Provide education and training in breastfeeding for all health professionals who care for women and children

Implementation Strategies | Potential Actors
Improve the breastfeeding content in undergraduate and graduate education and training for health professionals. | Health professional organizations Medical schools
Establish and incorporate minimum requirements for competency in lactation care into health professional credentialing, licensing, and certification processes. | Health professional organizations Credentialing boards
Increase opportunities for continuing education on the management of lactation to ensure the maintenance of minimum competencies and skills. | Health professional organizations Medical schools

Action 10 Include basic support for breastfeeding as a standard of care for midwives, obstetricians, family physicians, nurse practitioners, and pediatricians

Implementation Strategies | Potential Actors
Define standards for clinical practice that will ensure continuity of care for pregnant women and mother-baby pairs in the first four weeks of life. | HHS/HRSA^‡^ Health professional organizations
Conduct analyses and disseminate their findings on the comparative effectiveness of different models for integrating skilled lactation support into settings where midwives, obstetricians, family physicians, nurse practitioners, and pediatricians practice. | HHS/AHRQ^§^

‡ HHS/HRSA = U.S. Department of Health and Human Services/Health Resources and Services Administration.

§ HHS/AHRQ = U.S. Department of Health and Human Services/Agency for Healthcare Research and Quality.

Action 11 Ensure access to services provided by International Board Certified Lactation Consultants

Implementation Strategies | Potential Actors
Include support for lactation as an essential medical service for pregnant women, breastfeeding mothers, and children. | HHS/CMS^¶^ Third-party payers
Provide reimbursement for International Board Certified Lactation Consultants (IBCLCs) independent of their having other professional certification or licensure. | HHS/CMS Third-party payers
Work to increase the number of racial and ethnic minority IBCLCs to better mirror the U.S. population. | HHS/HRSA

¶ HHS/CMS = U.S. Department of Health and Human Services/Centers for Medicare & Medicaid Services.

Action 12 Identify and address obstacles to greater availability of safe banked donor milk for fragile infants

Implementation Strategies | Potential Actors
Conduct a systematic review of the current evidence on the safety and efficacy of donor human milk. | HHS/AHRQ
Establish evidence-based clinical guidelines for the use of banked donor milk. | HHS/MCHB^**^ Health professional organizations
Convene a study on federal regulation and support of donor milk banks. | Institute of Medicine

** HHS/MCHB = U.S. Department of Health and Human Services/Maternal and Child Health Bureau.

## Employment

Action 13 Work toward establishing paid maternity leave for all employed mothers

Implementation Strategies | Potential Actors
Add maternity leave to the categories of paid leave for federal civil servants. | Federal government State governments
Develop and implement programs in states to establish a funding mechanism for paid maternity leave. | State governments

Action 14 Ensure that employers establish and maintain comprehensive, high-quality lactation support programs for their employees

Implementation Strategies | Potential Actors
Develop resources to help employers comply with federal law that requires employers to provide the time and a place for nursing mothers to express breast milk. | DOL, HHS^*^ Public health entities Employer organizations
Design and disseminate materials to educate employers about the benefits of providing more comprehensive, high-quality support for breastfeeding employees. | Public health entities
Develop and share innovative solutions to the obstacles to breastfeeding that women face when returning to work in non-office settings. | DOL, HHS Public health entities Employers
Promote comprehensive, high-quality lactation support programs as part of a basic employee benefits package. | Employers

* DOL, HHS = U.S. Department of Labor; U.S. Department of Health and Human Services.

Action 15 Expand the use of programs in the workplace that allow lactating mothers to have direct access to their babies

Implementation Strategies | Potential Actors
Create incentive or recognition programs for businesses that establish, subsidize, and support child care centers at or near the business site. | Federal government State governments Community organizations
Identify and promote innovative programs that allow mothers to directly breastfeed their babies after they return to work. | Public health entities Employers Chambers of Commerce

Action 16 Ensure that all child care providers accommodate the needs of breastfeeding mothers and infants

Implementation Strategy | Potential Actors
Promote adoption of the breastfeeding standards in Caring for Our Children: National Health and Safety Performance Standards: Guidelines for Out-of-Home Child Care. | HHS/HRSA^†^ State governments

† HHS/HRSA = U.S. Department of Health and Human Services/Health Resources and Services Administration.

## Research and Surveillance

Action 17 Increase funding of high-quality research on breastfeeding

Implementation Strategy | Potential Actors
Designate additional research funding for studies on how to increase breastfeeding rates, the economics of breastfeeding, and management of lactation. | HHS/NIH^*^ Foundations

* HHS/NIH = U.S. Department of Health and Human Services/National Institutes of Health.

Action 18 Strengthen existing capacity and develop future capacity for conducting research on breastfeeding

Implementation Strategies | Potential Actors
Develop a national consortium on breastfeeding research. | HHS/NIH Researchers
Enhance the training of scientists in basic and applied research on lactation, breastfeeding, and women’s and children’s health. | HHS/NIH Universities and medical schools

Action 19 Develop a national monitoring system to improve the tracking of breastfeeding rates as well as the policies and environmental factors that affect breastfeeding

Implementation Strategies | Potential Actors
Enhance the CDC Breastfeeding Report Card by including a broader array of process indicators and showing trends over time. | HHS/CDC^†^
Collect data in all states on the initiation of breastfeeding and in-hospital supplementation with formula through the U.S. Standard Certificate of Live Birth. | State governments
Develop systems to collect key information on policy and environmental supports for breastfeeding. | HHS/CDC

† HHS/CDC = U.S. Department of Health and Human Services/Centers for Disease Control and Prevention.

## Public Health Infrastructure

Action 20 Improve national leadership on the promotion and support of breastfeeding

Implementation Strategies | Potential Actors
Create a federal interagency work group on breastfeeding. | Federal government
Increase the capacity of the United States Breastfeeding Committee and affiliated state coalitions to support breastfeeding. | Public health entities