# Acknowledgments

The Surgeon General’s Call to Action to Support Breastfeeding was prepared by the Centers for Disease Control and Prevention and the Office on Women’s Health under the direction of the Office of the Surgeon General. These three agencies are part of the U.S. Department of Health and Human Services, which published the Call to Action.

Regina Benjamin, M.D., M.B.A.

Vice Admiral, U.S. Public Health Service

Surgeon General

Thomas R. Frieden, M.D., M.P.H.

Director

Centers for Disease Control and Prevention

Wanda K. Jones, Dr.P.H.

Principal Deputy Assistant Secretary for Health

Office of the Assistant Secretary for Health

## Federal Steering Committee

Laurence Grummer-Strawn, Ph.D.

Scientific Editor

Captain, U.S. Public Health Service

Nutrition Branch Chief

Centers for Disease Control and Prevention

Suzanne Haynes, Ph.D.

Managing Editor

Senior Science Advisor

Office on Women’s Health

Office of the Assistant Secretary for Health

Mary Beth Bigley, Dr.P.H., M.S.N., A.N.P.

Contributing Editor

Acting Director, Office of Science and Communications

Office of the Surgeon General

Office of the Assistant Secretary for Health

Deborah Dee, Ph.D., M.P.H.

Lieutenant Commander, U.S. Public Health Service

Epidemiologist

Centers for Disease Control and Prevention

Sara Fein, Ph.D.

Consumer Science Specialist

Center for Food Safety and Applied Nutrition

U.S. Food and Drug Administration

Isadora Hare, M.S.W., L.C.S.W.

Perinatal Health Specialist

Maternal and Child Health Bureau

Health Resources and Services Administration

Tihesha Jenkins-Salley, M.P.H., R.D.

Nutritionist

Food and Nutrition Service

U.S. Department of Agriculture

Judith Labiner-Wolfe, Ph.D.

Evaluation Specialist

Office on Women’s Health

Office of the Assistant Secretary for Health

Ruowei Li, M.D., Ph.D.

Epidemiologist

Centers for Disease Control and Prevention

David Meyers, M.D.

Director

Center for Primary Care, Prevention, and Clinical Partnerships

Agency for Healthcare Research and Quality

Tonse Raju, M.D.

Medical Officer-Program Scientist

Eunice Kennedy Shriver National Institute of Child Health and Human Development

National Institutes of Health

Katherine Shealy, M.P.H., I.B.C.L.C.

Public Health Advisor

Centers for Disease Control and Prevention

Denise Sofka, M.P.H., R.D.

Public Health Analyst

Maternal and Child Health Bureau

Health Resources and Services Administration

Judith Thierry, D.O., M.P.H.

Captain, U.S. Public Health Service

Maternal and Child Health Coordinator

Indian Health Service