# Summary and Discussion

Currently, there are no validated decision aids or tools that adequately address the deactivation of electronic cardiac devices (ECDs). In contrast with current recommendations, existing decision aids do not address deactivation in discussions about insertion. Due to the lack of tools examining deactivation, generalizabililty to the Medicare population is not currently an issue.

We identified four decisions aids that addressed the insertion of pacemakers and implantable cardioverter-defibrillators (ICDs) in patients with heart failure and arrhythmia. Although it remains feasible that current recommendations could be incorporated into high-quality decisions aids for each type of ECD, there are consistent indications that other aspects of health care constitute barriers to high-quality decisionmaking and effective use of decision aids for the ICD population. These barriers include the following:

- Patients often have poor knowledge of key aspects related to deactivation, the role of the device, and how their health would be affected by deactivation of the device.
- Communication with physicians is often poor, and professionals are viewed as over-imposing their own values and priorities on patients.
- Key issues around informed consent, notably uncertainty, are not currently well understood.
- Patients reported wanting more discussions with a wider range of health professionals.
- The most common threats to informed consent were patient passivity, lack of information on the implications of deactivation for daily living activities, and the psychosocial disruption caused by devices, notably the shocks from ICDs.
- Patient experiences appeared to change over time. At 3 months after device insertion, there was a notably higher need for more information and psychosocial support.
- Limited social support existed for patients around decisionmaking or psychosocial wellbeing. Families and other caregivers were the main source of support, but were often seen to be overly protective.
- Psychosocial disruptions were common across ECDs. Studies reported that psychosocial disruptions were highest in patients with an ICD due to the frequency and intensity of shocks.
- Although current research presented limited sex- and age-based analyses, women appear to be prone to greater psychosocial sequelae from ICDs, and older adults may be more prone to lower social support.
- The main factors influencing anxiety and depression were: shock frequency, Type D personality, and social and educational status, and age.
- Communication-related factors that influenced psychosocial outcomes and quality of decisionmaking were the presence or absence of organizational policies around deactivation, the lack of training and comfort among health professionals in instigating and maintaining dialogue with patients around deactivation, and poorly-timed discussions that were too near to the end of the patient's life.
- Patients reported that they would welcome more discussion with health professionals around deactivation and would be comfortable having these discussions in person or over the telephone with wider members of the multidisciplinary health care team.

These issues pertain across ECDs but are of particular relevance to ICDs.

Patient accounts of and satisfaction with decisionmaking around deactivation and insertion are an important part of ensuring informed consent. This review identified that common barriers to attaining and maintaining this consent are: gaps in basic knowledge about devices, disparities in values between patients and health professionals, and patient anxiety. More positively, patients do appear to want to be more involved, be more informed, and receive support from different professional groups.

Deactivation of an ECD is an important aspect of health care that should be discussed openly, instigated by the primary physician, early in the care trajectory and prior to insertion of the device. However, there is consistent evidence that physicians are not well trained to initiate and maintain this dialogue, that values and priorities of patients and professionals can be incongruent, and that patients often lack basic knowledge that will allow them to make choices about deactivation in an informed manner. Moreover, there was limited evidence that caregivers and family provide support that patients perceive as useful around deactivation decisions. Decisions about deactivation are likely to be complex due to the prevalence and negative effects of shocks on psychosocial wellbeing, particularly during the first year after insertion. Nevertheless, patients have voiced both a need and desire for more comprehensive information about the implications of deactivation and for support from other health professionals.

Health professionals have expressed different opinions over the legality and ethics of deactivation of ECDs. Clinicians have markedly different levels of comfort in addressing deactivation decisions, and different views of their role and of the ethics and legality of these decisions. The ability to generalize from these studies to the United States is constrained because current research has been based on relatively small qualitative studies and surveys that have been mostly local and/or had relatively low response rates. Further, ECD deactivation emerged as a new and contentious issue only in recent years and has thus far been characterized by a lack of consensus and guidance around practice, policy, and legal and ethical aspects.

This review identified research on patient perspectives regarding decisionmaking around ECDs. Although the overall quality of the qualitative, quantitative, and mixed method studies included in the review was moderate, most research has focused on aspects of insertion decisions. Even when deactivation was addressed, this was seldom done from the perspective of end-of-life care. Also, there was very little existing evidence on decisionmaking about ECDs by surrogate decisionmakers. The prevalence and quality of decisions about ECD deactivation made by surrogate decisionmakers is therefore unknown. Similarly, how family members are involved and their own satisfaction with decisionmaking about ECD deactivation is not well understood.

It is not necessarily surprising that there are no existing decision tools that adequately address deactivation either prior to insertion as part of the decision to insert the ECD or after insertion as a discrete decision. Clear guidance on the most contentious issues around deactivation relating to ICDs was only published in 2010.^35^ Many of the concerning patterns identified in this review around informed consent for the deactivation of ICDs predate this guidance, and there was a lack of consensus prior to this around the ethics and legality of deactivation evident in both argument12-15 and practice.16

These guidelines may in time influence organizational policies and health care practice in relation to deactivation of ICDs and other ECDs, for which the same ethical and legal principles apply. That said, the recognition that deactivation of an ICD does not constitute an act of euthanasia or assisted suicide37,38 and has the same legal and ethical status as withdrawal of any treatment does not guarantee that care is legal and ethical. Rather, high-quality decisionmaking that supports the principles and practices of informed consent and patient involvement in decisions is the best means to ensure care is legal and ethical.

Practitioners' ability to attain and maintain informed consent may be constrained by the wide prevalence in patients of basic knowledge gaps that exist not only in device function, efficacy, and implications of deactivation, but also in knowledge of underlying health conditions. Although it may be surprising that such knowledge gaps exist even after years of treatment, similar gaps are relatively common in patients with advanced heart failure.151-153 Systematic reviews have demonstrated that untreated and unrecognized anxiety and depression are common in patients with all forms of coronary heart disease154 and heart failure.155 As such, many of the psychosocio-educational challenges in maintaining informed consent in people with ECDs occur in patients with other cardiac conditions and may be amenable to similar solutions.

## Future Research

To support legal and ethical decisionmaking around ECDs, decision tools should be developed for insertion that incorporate issues of deactivation. Due to differences in device purpose and underlying conditions, different tools will be required for different types of ECDs (i.e., ICD, including cardiac resynchronization therapy [CRT] and non-CRT, pacemaker, and ventricular assist device [VAD]) and different patient populations. Current tools to inform decisions about insertion of pace makers82,84 and ICDs81,83 should incorporate a discussion of deactivation, not only because this is recommended by guidelines,35 but because such discussions are integral to ensuring adequate informed consent prior to insertion. In all instances, further research is needed to ensure that each tool is of high quality; this can be assessed using recognized quality criteria.68

In the light of current guidelines in the United States35 and elsewhere,8 high-quality decision tools focusing on deactivation of ECDs are urgently needed. These tools should follow a systematic development process, provide information on options, explain the probabilities involved in clear and numerical ways, and provide guidance on how to communicate with health professionals.68 Further, the aids should be based on the latest scientific evidence, use plain language, and present information in a balanced manner.68 As with insertion, separate tools around deactivation are needed for different patient populations and ECDs. Research should focus on the quality of these aids68 and also what influences their effectiveness when used in health care systems.

However, common and substantial barriers to the effectiveness of tools that will not be ameliorated by the use of decision aids relate to the wider communication and consent processes. There is an urgent need for a U.S. national survey of relevant care settings to determine what proportion have policies in place related to deactivation of ECDs, particularly of ICDs in patients with heart failure or arrhythmia. This survey is an important extension to a recent national survey of hospice policy.61

Physician attitudes and practices around deactivation of ICDs should be reassessed in key clinical groups in the light of recent guidelines on key processes of care and consent.35 The perceived congruence between the legal and ethical acceptability of ICDs from the perspective of practitioners to current American Medical Association (AMA) positions37-39,156 and guidelines35 should be ascertained. Other topics that merit further exploration via surveys include:

- Physician readiness to involve other professional groups in patient support and discussions around deactivation;
- The degree and nature of collaboration that exists between cardiology and palliative care teams in deactivation decisions;
- Uncertainty and how this is addressed in communication between patients, next-of-kin and health professionals, and
- The views of informed consent and reported practices of physicians around deactivation decisions compared with professional statements33,113 and relevant guidelines.35

Future interventions to support patient wellbeing and high-quality decisions should focus on training clinicians in communication and decisionmaking and promoting patient involvement, receptivity to discussions, and psychosocial wellbeing.

Further training of health professionals involved in deactivation decisions should be evaluated prior to implementation. The effectiveness of training could be evaluated using randomized control trials (RCTs) with patient-centered outcomes to determine adequacy of consent, such as patient knowledge, content, involvement, and timing of discussions. Interventions to support training of health professionals should address the different roles that physicians and other professional groups may have in deactivation discussions and should incorporate recommendations from guidelines.35 In addition, they should address the receptiveness of patients or surrogate decisionmakers to these discussions in the light of their values and preferences, adverse psychosocial factors, and gaps in basic knowledge about ECDs. Training resources have been developed in other countries that may be transferable to the United States. Since 2007, the British Heart Foundation has adopted a policy of advanced communication skills training as integral to their heart failure nurse training curriculum.157

Most adverse psychosocial outcomes occur in patients after ICD insertion. Women are particularly vulnerable to anxiety.114,130,136,139 Patient anxiety can be addressed by reducing the risk of inappropriate shocks;158 for example, U.S. guidelines now exist on specific programming strategies or pharmacotherapy to suppress arrhythmias.159 Systematic reviews and trials suggest that dedicated programs of cognitive behavioral therapy78,160 and psycho-education79,161 may also have positive effects on anxiety in ICD patients. A narrative review showed that interventions tailored to individual needs can address a wide range of ICD-related anxieties, including device acceptance, shock anxiety, and death anxiety. These interventions can be specifically targeted to women, young patients, and next-of-kin.162 Key components of these interventions include device-related education, relaxation and stress management, cognitive restructuring, social support and group discussion, and exercise.162 The development and testing of electronic or telehealth interventions to promote access to hard-to-reach populations, such as patients from rural communities, are important and have been shown to be effective in for other cardiac conditions.163-166

## Applicability

The applicability of the findings to the Medicare population is constrained by the relatively young mean age of participants in most studies and a lack of incorporating age into analyses. The expansion of Medicare reimbursement of ICDs, and the resultant increasing prevalence of ICDs in the Medicare population, point to the need to improve practice and outcomes in this large and potentially vulnerable population.1 Although a small number of studies indicated that age may ameliorate some of the anxiety associated with shocks,115,120 the influence of age on patient experiences and outcomes has not been specifically examined in studies to date. Future studies should specifically examine the degree to which age moderates key elements of care, including attitudes to involvement in decisionmaking, factors considered and weight given to these factor, and the roles of other family members.

Similarly, surrogate decisionmakers remain absent from existing research, despite having a potentially pivotal involvement in making decisions for patients who do not have capacity to understand choices around deactivation and/or make decisions about deactivation.35

## Conclusions

We identified four decision aids that addressed insertion of pacemakers and ICDs in patients with heart failure and arrhythmia. There are no existing validated decision aids or tools that adequately address the deactivation of ECDs.

In contrast with current recommendations, none of the aids for ICDs, pacemakers, or left ventricular assist devices addressed deactivation in discussions about insertion. Insertion was partially addressed by the tools, with quality reduced by the lack of focus in discussions prior to insertion of deactivation. Due to the lack of tools examining deactivation, the representation of the Medicare population is not currently an issue.

Although current recommendations could be incorporated into high-quality decisions aids for each type of ECD, there are consistent indications that other aspects of health care constitute barriers to high-quality decisionmaking and effective use of decision aids. There was consistent evidence from the qualitative research that patients often have poor knowledge of basic elements related to deactivation, including the role of the device and how their health would be affected by its deactivation. Communication with physicians was often poor, and patients perceived that professionals over-imposed their own values and priorities. Patients reported wanting more discussions with a wider range of health professionals. The most common threats to informed consent were patient passivity, lack of information on the implications of deactivation for daily living activities, and the psychosocial disruption caused by devices, notably the shocks from ICDs. Patient experiences appeared to change over time. The need for more information and psychosocial support was highest at 3 months after insertion. Continued social support for patients around decisionmaking or psychosocial wellbeing was limited. When support was provided, families and other caregivers were the main source, but were often seen to be overly protective.

Psychosocial disruptions were common across all ECDs, but were greater for ICDs due to the frequency and intensity of shocks. Although current research presented limited sex- and age-based analyses, women appeared to be prone to greater psychosocial sequelae from ICDs, and older adults may be more prone to lower social support.

The quantitative studies of psychosocial outcomes corroborated the qualitative findings. The main factors influencing anxiety and depression were shock frequency, Type D personality, social and educational status, and age.

Communication-related factors that influenced psychosocial outcomes and quality of decisionmaking were: the presence or absence of organizational policies around deactivation, the lack of training and comfort among health professionals in initiating and maintaining dialogue, and poorly timed discussions that were too near patients' end of life. Patients reported that they would welcome more discussion with health professionals around deactivation and would be comfortable having these discussions in person or over the telephone with wider members of the multidisciplinary health care team.