# References

1 Kaufman SR, Mueller PS, Ottenberg AL, et al. Ironic technology: old age and the implantable cardioverter defibrillator in US health care. Soc Sci Med. 2011;72(1):6-14. [pmid: 21126815].
2 Hammill SC, Kremers MS, Stevenson LW, et al. National ICD Registry annual report 2009 review of the registry's fourth year, incorporating lead data and pediatric ICD procedures, and use as a national performance measure. Heart Rhythm. 2010. [pmid: 20647056].
3 Al-Khatib SM, Helkamp A, Curtis J, et al. Non-evidence based ICD implantations in the United States. JAMA. 2011;305(1):43-49. [pmid: 21205965].
4 Poole JE, Fishbein D, Crossley GH. ICD Implantation and evidence-based patient selection. JAMA. 2011;305(15):1537. [pmid: 21505127].
5 Blake K, Swerdlow CD. ICD Implantation and evidence-based patient selection. JAMA. 2011;305(15):1538. [pmid: 21505129].
6 Brignole M. Are complications of implantable defibrillators under-estimated and benefits over estimated?. Europace. 2009;11:1129-33. [pmid: 19578174].
7 Tung R, Zimerman P, Josephson ME. A critical appraisal of implantable cardioverter-defibrillator theray for the prevention of sudden cardiac death. J Am Coll Cardiol. 2008;52(14):1111-21. [pmid: 18804736].
8 Padeletti L, Arnar D, Boncinelli L, et al. EHRA Expert Consensus Statement on the management of cardiovascular implantable electronic devices in patients nearing end of life or requesting withdrawal of therapy. Europace. 2010;12(10):1480-89. [pmid: 20675674].
9 Gawande A. Letting go. What should medicine do when it can't save your life?. 2010. Aug. 2. [cited 2011 July 4]. The New Yorker © 2011. Available from: http://www.newyorker.com/reporting/2010/08/02/100802fa_fact_gawande?currentPage=all#ixzz0uuAGwOwQ.
10 Pear R. Obama returns to end-of-life plan that caused stir. 2010. Dec. 25. [cited 2011 July 4]. New York Times © 2011. Available from: http://www.nytimes.com/2010/12/26/us/politics/26death.html?pagewanted=1.
11 Stein R. Heart pump creates life-death ethical dilemmas. 2008. April. 24. [cited 2011 July 4]. Washington Post © 1996-2011. Available from: http://www.washingtonpost.com/wp-dyn/content/article/2008/04/23/AR2008042303534.html.
12 Lewis WR, Luebke DL, Johnson NJ, et al. Withdrawing implantable defibrillator shock therapy in terminally ill patients. Am J Med. 2006;119(10):892-6. [pmid: 17000222].
13 Braun TC, Hagen NA, Hatfield RE, et al. Cardiac pacemakers and implantable defibrillators in terminal care. J Pain Symtom Manag. 1999;18:126-31. [pmid: 10484960].
14 Berger JT. The ethics of deactivating implanted cardioverter defibrillators. Ann Intern Med. 2005;142:631-34. [pmid: 15838070].
15 Kapa S, Rotondi-Trevisan D, Mariano Z, et al. Psychopathology in patients with ICDs over time: results of a prospective study. Pacing Clin Electrophysiol. 2010;33(2):198-208. [pmid: 19930108].
16 Sherazi S, Daubert J, Block R, et al. Physicians' preferences and attitudes about end-of-life care in patients with an implantable cardioverter-defibrillator. Mayo Clin Proc. 2008;83:1139-41. [pmid: 18828973].
17 Francis GS, Greenberg BH, Hsu DT, et al. ACCF/AHA/ACP/HFSA/ISHLT 2010 clinical competence statement on management of patients with advanced heart failure and cardiac Transplant: a report of the ACCF/AHA/ACP Task Force on clinical competence and training. Circulation. 2010;122:644-72. [pmid: 20644017].
18 Mueller PS, Jenkins SM, Bramstedt KA, et al. Deactivating implanted cardiac devices in terminally ill patients: practices and attitudes. Pacing Clin Electrophysiol. 2008;31:560-8. [pmid: 18439169].
19 McGeary A, Eldergill A. Medicolegal issues arising when pacemaker and implantable cardioverter defibrillator devices are deactivated in terminally ill patients. Med Sci Law. 2010;50:40-4. [pmid: 20349694].
20 Basta E. End-of-life and other ethical issues related to pacemaker and defibrillator use in the elderly. Am J Geriatr Cardiol. 2006;15:114-7. [pmid: 16525225].
21 Zellner R, Aulisio MP, Lewis WR. Should implantable cardio-verter defibrillators and permanent pacemakers in patients with terminal illness be deactivated?. Circ Arrythm Electrophysiol. 2009;2:340-44. [pmid: 19808485].
22 Brush S, Budge D, Alharethi R, et al. End-of-life decisionmaking and implementation in recipients of a destination left ventricular assist device. J Heart Lung Transpl. 2011;29:1337-441. [pmid: 20817564].
23 Rizzieri AG, Verheijde JL, Rady MY, et al. Ethical challenges with the left ventricular assist devices as a destination therapy. Philos Ethics Humanit Med. 2008;3(20). [pmid: 18694496].
24 Bramstedt KA. Destination nowhere: a potential dilemma with ventricular assist devices. ASAIO J. 2008;54(1):1-2. [pmid: 18204307].
25 Karlawish JHT, Fox E, Pearlman R. How changes in health care practices, systems, and research challenge the practice of informed consent. Med Care. 2002;40(Suppl 9):V12-19. [pmid: 12226581].
26 Guyatt G, Rennie D, Meade M, et al. User's guide to the medical literature. New York. American Medical Association. 2008.
27 Guyatt G, Haynes B, Jaeschke R, et al. Introduction: The Philosophy of Evidence-based Medicine. Guyatt G, Rennie D, editors. User's guides to the Medical Literature. Chicago. American Medical Association. 2002:5-20.
28 Kim SYH. Evaluation of capacity to consent to treatment and research. Oxford. Oxford University Press. 2009.
29 General Medical Council. Treatment and care towards the end of life: good practice in decisionmaking. London. General Medical Council. 2010. [cited 2011 July 4]. Available from: http://www.gmc-uk.org/End_of_life.pdf_32486688.pdf.
30 del Carmen MG, Joffe S. Informed consent for medical treatment and research: a review. The Oncologist. 2005;10:636-41. [pmid: 16177288].
31 Downie RS, Calmanm KC. Healthy Respect: Ethics in Healthcare. Oxford. Oxford University Press. 1994.
32 Department of Health. Good practice in consent implementation guide: consent to examination or treatment. London. Department of Health. 2001. [cited 2011 July 4]. Available from: http://www.dh.gov.uk/prod_consum_dh/groups/dh_digitalassets/@dh/@en/documents/digitalasset/dh_4019061.pdf.
33 American Medical Association. H-320.951 AMA Opposition to “Procedure-Specific” Informed Consent. [cited 2011 July 4]. Available from: https://ssl3.ama-assn.org/apps/ecomm/PolicyFinderForm.pl?site=www.ama-assn.org&uri=%2fresources%2fdoc%2fPolicyFinder%2fpolicyfiles%2fHnE%2fH-320.951.HTM.
34 American Medical Association. E-8.081 Surrogate Decision-Making. 2004. [cited 2011 July 4]. Available from: https://ssl3.ama-assn.org/apps/ecomm/PolicyFinderForm.pl?site=www.ama-assn.org&uri=%2fresources%2fdoc%2fPolicyFinder%2fpolicyfiles%2fHnE%2fE-8.081.HTM.
35 Lampert R, Hayes DL, Annas GJ, et al. HRS expert consensus statement on the management of Cardiovascular Implantable Electronic Devices (CIEDs) in patients nearing end of life or requesting withdrawal of therapy. Heart Rhythm. 2010;7(7):1008-26. [pmid: 20471915].
36 Hamel R. Implantable cardiac devices at life's end: is deactivation morally licit?. Health Care Ethics. 2010;18(3):2-7.
37 American Medical Association. E–2.211 Physician-Assisted Suicide. 1996. [cited 2011 July 4]. Available from: https://ssl3.ama-assn.org/apps/ecomm/PolicyFinderForm.pl?site=www.ama-assn.org&uri=%2fresources%2fdoc%2fPolicyFinder%2fpolicyfiles%2fHnE%2fE-2.211.HTM.
38 American Medical Association. E–2.21 Euthanasia. 1996. [cited 2011 July 4]. Available from: https://ssl3.ama-assn.org/apps/ecomm/PolicyFinderForm.pl?site=www.ama-assn.org&uri=%2fresources%2fdoc%2fPolicyFinder%2fpolicyfiles%2fHnE%2fE-2.21.HTM.
39 American Medical Association. E–2.22 Do-Not-Resuscitate Orders. 2005. [cited 2011 July 4]. Available from: https://ssl3.ama-assn.org/apps/ecomm/PolicyFinderForm.pl?site=www.ama-assn.org&uri=%2fresources%2fdoc%2fPolicyFinder%2fpolicyfiles%2fHnE%2fE-2.22.HTM.
40 Sulmasy DP. Within you/without you: biotechnology, ontology and ethics. J Gen Intern Med. 2007;23(Suppl 1):69-72. [pmid: 18095048].
41 Dudzinski DM. Ethics guidelines for destination therapy. Ann Thorac Surg. 2006;81:1185-8. [pmid: 16564238].
42 Goldstein NE, Lampert R, Bradley E, et al. Management of implantable cardioverter defibrillators in end-of-life care. Ann Intern Med. 2004;141:835-38. [pmid: 15583224].
43 Marinskis G, van Erven L, EHRA Scientific Initiatives Committee. Deactivation of implanted cardioverter-defibrillators at the end of life: results of the EHRA Survey. Europace. 2010;12:1176-77. [pmid: 20663788].
44 Goldstein N, Bradley E, Zeidman J, et al. Barriers to conversations about deactivation of implantable defibrillators in seriously ill patients. J Am Coll Cardiol. 2009;54(4):371-4. [pmid: 19608038].
45 Goldstein NE, Mehta D, Siddiqui S, et al. “That's like an act of suicide” patients' attitudes toward deactivation of implantable defibrillators. J Gen Intern Med. 2008;23(Suppl 1):7-12. [pmid: 18095037].
46 Goldstein NE, Mehta D, Teitelbaum E, et al. “It's like crossing a bridge” complexities preventing physicians from discussing deactivation of implantable defibrillators at the end of life. J Gen Intern Med. 2008;23(Suppl 1):2-6. [pmid: 18095036].
47 Strachan PH, Carroll SL, de Laat D, et al. Patients' perspectives on end-of-life issues and implantable cardioverter defibrillators. J Palliative Care. 2011;27:6-11. [pmid: 21510126].
48 Zayac S, Finch N. Recipients' of implanted cardioverter-defibrillators actual and perceived adaptation: a review of the literature. J Am Acad Nurse Pract. 2009;21:549-56. [pmid: 19796289].
49 Hunt SA, Abraham WT, Chin MH, et al. 2009 focused update incorporated into the ACC/AHA 2005 guidelines for the diagnosis and management of heart failure in adults: a report of the American College of Cardiology Foundation/American Heart Association task force on practice guidelines. Circulation. 2009;119:e391-e479. [pmid: 19324966].
50 Jaarsma T, Beattie JM, Ryder M, et al. Palliative care in heart failure: a position statement from the palliative care workshop of the Heart Failure Association of the European Society of Cardiology. Eur J Heart Fail. 2009;11(5):433-43. [pmid: 19386813].
51 Liew R. Implantable cardioverter defibrillators after acute myocardial infarction. BMJ. 2010;341:c5741. [pmid: 21097570].
52 Myerburg RJ. Implantable cardioverter-defibrillators after myocardial infarction. New Engl J Med. 2008;359:2245-53. [pmid: 19020326].
53 Powell TP, Oz MC. Discontinuing the LVAD: ethical considerations. Ann Thorac Surg. 1997;63:1223-4. [pmid: 9146305].
54 Myerburg RJ, Mitrani R, Interian A, et al. Interpretation of outcomes of antiarrythmic clinical trials: design features and population impact. Circulation. 1998;97:1514-21. [pmid: 9576433].
55 Goldberger JJ, Cain ME, Hohnloser SH, et al. American Heart Association/American College of Cardiology/Heart Rhythm Society scientific statement on noninvasive risk stratification techniques for identifying patients at risk for sudden cardiac death. J Am Coll Cardiol. 2008;52(4):1179-99. [pmid: 18804749].
56 Piccini JP, S AZ, Horton JR, et al. Single photon emission computed tomography myocardial perfusion imaging and the risk of sudden cardiac death in patientas with coronary disease and left ventricular ejection fraction > 35%. J Am Coll Cardiol. 2010;56:206-14. [pmid: 20620740].
57 Myerburg RJ, Hendel RC. Expanding risk profiling strategies for prediction and prevention of sudden cardiac death. J Am Coll Cardiol. 2010;56(3):215-17. [pmid: 20620741].
58 Kelley AS, Reid MC, Miller DH, et al. Implantable cardioverter-defibrillator deactivation at the end of life: a physician survey. Am Heart J. 2009;157(4):702-8. [pmid: 19332199].
59 Sears SF, Todaro JF, Urizar G, et al. Assessing the psychosocial impact of the ICD: a national survey of implantable cardioverter defibrillator health care providers. Pacing Clin Electrophysiol. 2000;23:939-45. [pmid: 10879376].
60 Mueller PS, Hook CC, Hayes D. Ethical analysis of withdrawal of pacemaker or implantable cardioverter-defibrillator support at the end of life. Mayo Clin Proc. 2003;7:959-63. [pmid: 12911044].
61 Goldstein N, Carlson M, Livote E, et al. Management of implantable cardioverter-defribrillators in hospice: a nationwide survey. Ann Intern Med. 2010;152:296-99. [pmid: 20194235].
62 Morrison LJ, Calvin AO, Nora H, et al. Managing cardiac devices near the end of life: a survey of hospice and palliative care providers. Am J Hosp Palliat Care. 2010;27:545-51. [pmid: 20713422].
63 O'Connor AM, Bennett CL, Stacey D, et al. Decision aids for people facing health treatment or screening decisions. Cochrane Database Syst Rev. 2009;(3). CD001431. [pmid: 19588325].
64 O'Connor AM, Rostom A, Fiset V, et al. Decision aids for patients facing health treatment or screening decisions: systematic review. BMJ. 1999;319:731-34. [pmid: 10487995].
65 O'Connor AM, Wennberg JE, Legare F, et al. Toward the ‘tipping point’: decision aids and informed patient choice. Health Affair. 2007;26(3):716-25. [pmid: 17485749].
66 International Patient Decision Aid Standards Collaboration. What are patient decision aids?. [cited 2011 July 4]. Available from: http://ipdas.ohri.ca/what.html.
67 Jadad AR, Moore RA, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
68 Elwyn G, O'Connor A, Stacey D, et al. Developing a quality criteria framework for patient decision aids: online international Delphi consensus process. BMJ. 2006;333(7565):417. [pmid: 16908462].
69 Critical Appraisal Skills Programme (CASP) and Evidence-based Practice: CASP qualitative appraisal tool. NHS Learning and Development. 2007. [cited 2011 July 4]. Available from: http://www.sph.nhs.uk/sph-files/casp-appraisal-tools/Qualitative%20Appraisal%20Tool.pdf.
70 Feder GS, Hutson M, Ramsay J, et al. Women exposed to intimate partner violence: expectations and experiences when they encounter health professionals: a meta analysis of qualitative studies. Arch Intern Med. 2006;166:22-37. [pmid: 16401807].
71 NHS Learning and Development. Critical Appraisal Skills (CASP) and Evidence-based Practice: CASP cohort studies tool. 2004. [cited 2011 July 4]. Available from: http://www.sph.nhs.uk/sph-files/casp-appraisal-tools/cohort%2012%20questions.pdf.
72 11 questions to help you make sense of descriptive/cross-sectional studies. Albert Einstein College of Medicine of Yeshiva University NY. 2002. [cited 2011 July 4]. Available from: http://www.yu.edu/aecomdb/dfsm/Uploads/ugclerkshipinfo/cross-sectional%20study%20appraisal%20tool.pdf.
73 Noblit G, Hare R. Meta-ethnography: synthesizing qualitative data. London. Sage. 1988.
74 Pound P, Britten N, Morgan M, et al. Resisting medicines: a synthesis of qualitative studies of medication taking. Soc Sci Med. 2005;61:133-55. [pmid: 15847968].
75 Mays N, Pope C, Popay J. Systematically reviewing qualitative and quantitative evidence to inform management and policy making in the health field. J Health Serv Res Policy. 2005;10(Suppl 1):6-20. [pmid: 16053580].
76 Whittemore R, Knafl K. The integrative review: updated methodology. J Adv Nurs. 2005;52:546-53. [pmid: 16268861].
77 Dougherty CM, Lewis FM, Thompson EA, et al. Short-term efficacy of a telephone intervention by expert nurses after an implantable cardioverter defibrillator. Pacing Clin Electrophysiol. 2004;27(12):1594-602. [pmid: 15613121].
78 Lewin RJ, Coulton S, Frizelle DJ, et al. A brief cognitive behavioural preimplantation and rehabilitation programme for patients receiving an implantable cardioverter-defibrillator improves physical health and reduces psychological morbidity and unplanned readmissions. Heart. 2009;95:63-69. [pmid: 18070951].
79 Dunbar SB, Langberg JJ, Reilly CM, et al. Effect of a psychoeducational intervention on depression, anxiety, and health resource use in implantable cardioverter defibrillator patients. Pacing Clin Electrophysiol. 2009;32(10):1259-71. [pmid: 19796343].
80 Kirchhoff KT, Hammes BJ, Kehl KA, et al. Effect of a disease-specific planning intervention on surrogate understanding of patient goals for future medical treatment. J Am Geriatr Soc. 2010;58(7):1233-40. [pmid: 20649686].
81 Heart rate problems: should I get an implantable cardioverter-defibrillator (ICD)?. Healthwise Knowledgebase © 1995–2011. [cited 2011 July 4]. Available from: http://www.healthwise.net/fchp/Content/StdDocument.aspx?DOCHWID=abk4103.
82 Heart rate problems: should I get a pacemaker?. Healthwise Knowledgebase © 1995–2011. [cited 2011 July 4]. Available from: http://www.healthwise.net/fchp/Content/StdDocument.aspx?DOCHWID=abk4063.
83 Heart failure: should I get an implantable cardioverter-defibrillator (ICD)?. Healthwise Knowledgebase © 1995–2011. [cited 2011 July 4]. Available from: http://www.healthwise.net/fchp/Content/StdDocument.aspx?DOCHWID=uf9843.
84 Heart failure: should I get a pacemaker (cardiac resynchronization therapy)?. Healthwise Knowledgebase © 1995–2011. [cited 2011 July 4]. Available from: http://www.healthwise.net/fchp/Content/StdDocument.aspx?DOCHWID=uf9843.
85 Anderson CC. The postmodern heart: war veterans' experiences of invasive cardiac technology. J Adv Nurs. 2004;46(3):253-61. [pmid: 15066103].
86 Bolse K, Hamilton G, Flanagan J, et al. Ways of experiencing the life situation among United States patients with an implantable cardioverter-defibrillator: a qualitative study. Prog Cardiovasc Nurs. 2005;20(1):4-10. [pmid: 15785164].
87 Burke LJ. Securing life through technology acceptance: the first six months following implantation of a transvenous internal cardioverter defibrillator [dissertation]. Milwaukee. University of Wisconsin - Milwaukee. 1995.
88 Dougherty CM, Benoliel JQ, Bellin C. Domains of nursing intervention after sudden cardiac arrest and automatic internal cardioverter defibrillator implantation. Heart Lung. 2000;29(2):79-86. [pmid: 10739483].
89 Berger JT, Gorski M, Cohen T. Advance health planning and treatment preferences among recipients of implantable cardioverter defibrillators: an exploratory study. J Clin Ethics. 2006;17(1):72-8. [pmid: 16689116].
90 Bolse K, Flemme I, Ivarsson A, et al. Life situation related to the ICD implantation; self-reported uncertainty and satisfaction in Swedish and US samples. Eur J Cardiovasc Nurs. 2002;1(4):243-51. [pmid: 14622654].
91 Dougherty CM. Longitudinal recovery following sudden cardiac arrest and internal cardioverter defibrillator implantation: survivors and their families. Am J Crit Care. 1994;3(2):145-54. [pmid: 8167775].
92 Flemme I, Bolse K, Ivarsson A, et al. Life situation of patients with an implantable cardioverter defibrillator: a descriptive longitudinal study. J Clin Nurs. 2001;10(4):563-72. [pmid: 11822504].
93 Sossong A. Living with an implantable cardioverter defibrillator: patient outcomes and the nurse's role. J Cardiovasc Nurs. 2007;22(2):99-104. [pmid: 17318034].
94 Wallace RL, Sears SF Jr., Lewis T, et al. Predictors of quality of life in long-term recipients of implantable cardioverter defibrillators. J Cardiopulm Rehab. 2002;22(4):278-81. [pmid: 12202849].
95 Eckert M, Jones T. How does an implantable cardioverter defibrillator (ICD) affect the lives of patients and their families?. Int J Nurs Pract. 2002;8(3):152-57. [pmid: 12000634].
96 Matlock DD, Nowels CT, Bekelman D. Patient perspectives on decision making in heart failure. J Card Fail. 2011;16(10):823-26. [pmid: 20932464].
97 Sneed NV, Finch N. Experiences of patients and significant others with automatic implantable cardioverter defibrillators after discharge from the hospital. Prog Cardiovasc Nurs. 1992;7(3):20-24. [pmid: 1297142].
98 Steinke EE, Gill-Hopple K, Valdez D, et al. Sexual concerns and educational needs after an implantable cardioverter defibrillator. Heart Lung. 2005;34(5):299-308. [pmid: 16157184].
99 Tagney J, James JE, Albarran JW. Exploring the patient's experiences of learning to live with an implantable cardioverter defibrillator (ICD) from one UK centre: a qualitative study. Eur J Cardiovasc Nurs. 2003;2(3):195-203. [pmid: 14622627].
100 Williams AM, Young J, Nikoletti S, et al. Reasons for attending and not attending a support group for recipients of implantable cardioverter defibrillators and their carers. Int J Nurs Pract. 2004;10(3):127-33. [pmid: 15149460].
101 Agard A, Lofmark R, Edvardsson N, et al. Views of patients with heart failure about their role in the decision to start implantable cardioverter-defibrillator treatment: prescription rather than participation. J Med Ethics. 2007;33(9):514-18. [pmid: 17761818].
102 Andersen J, Oyen N, Bjorvatn C, et al. Living with long QT syndrome: a qualitative study of coping with increased risk of sudden cardiac death. J Genet Couns. 2008;17(5):489-98. [pmid: 18719982].
103 Beery TA. The experience of living with an implanted biotechnical device: a qualitative study of women with cardiac pacemakers [dissertation]. Cincinnati. University of Cincinnati. 1998.
104 Dickerson SS. Redefining life while forestalling death: living with an implantable cardioverter defibrillator after a sudden cardiac death experience. Qual Health Res. 2002;12(3):360-72. [pmid: 11918101].
105 Beery TA, Sommers MS, Hall J. Focused life stories of women with cardiac pacemakers. West J Nurs Res. 2002;24(1):7-27. [pmid: 11829275].
106 Dunbar SB, Warner CD, Purcell JA. Internal cardioverter defibrillator device discharge: Experiences of patients and family members. Heart Lung. 1993;22(6):494-501. [pmid: 8288452].
107 Fridlund B, Lindgren EC, Ivarsson A, et al. Patients with implantable cardioverter-defibrillators and their conceptions of the life situation: a qualitative analysis. J Clin Nurs. 2000;9(1):37-45. [pmid: 11022491].
108 Noyes K, Corona E, Veazie P, et al. Examination of the effect of implantable cardioverter-defibrillators on health-related quality of life: based on results from the Multicenter Automatic Defibrillator Trial-II. Am J Cardiovasc Drugs. 2009;9(6):393-400. [pmid: 19929037].
109 Prudente LA, Reigle J, Bourguignon C, et al. Psychological indices and phantom shocks in patients with ICD. J Interv Card Electrophysiol. 2006;15(3):185-90. [pmid: 17019638].
110 Gibson D, Kuntz K, Levenson J, et al. Decision-making, emotional distress, and quality of life in patients affected by the recall of their implantable cardioverter defibrillator. Europace. 2008;10(5):540-4. [pmid: 18442964].
111 Ong L. Predicting psychological outcomes and antiarrhythmic therapies of defibrillator recipients: the role of dispositional vulnerability [dissertation]. Toronto. York University. 2008.
112 Stewart GC, Weintraub JR, Pratibhu PP, et al. Patient expectations from implantable defibrillators to prevent death in heart failure. J Cardiac Fail. 2010;16(2):106-13. [pmid: 20142021].
113 American Medical Association. H-140.989 Informed Consent and Decision-Making in Health Care. [cited 2011 July 4]. Available at: https://ssl3.ama-assn.org/apps/ecomm/PolicyFinderForm.pl?site=www.ama-assn.org&uri=%2fresources%2fdoc%2fPolicyFinder%2fpolicyfiles%2fHnE%2fH-140.989.HTM.
114 Bilge AK, Ozben B, Demircan S, et al. Depression and anxiety status of patients with implantable cardioverter defibrillator and precipitating factors. Pacing Clin Electrophysiol. 2006;29(6):619-26. [pmid: 16784428].
115 Birnie DH, Sears SF, Green MS, et al. No long-term psychological morbidity living with an implantable cardioverter defibrillator under advisory: the Medtronic Marquis experience. Europace. 2009;11(1):26-30. [pmid: 19010798].
116 Carroll SL, Arthur HM. A comparative study of uncertainty, optimism and anxiety in patients receiving their first implantable defibrillator for primary or secondary prevention of sudden cardiac death. Int J Nurs Stud. 2010;47(7):836-45. [pmid: 20064639].
117 Duru F, Buchi S, Klaghofer R, et al. How different from pacemaker patients are recipients of implantable cardioverter-defibrillators with respect to psychosocial adaptation, affective disorders, and quality of life?. Heart. 2001;85(4):375-79. [pmid: 11250956].
118 Serber ER, Sears SF, Sotile RO, et al. Sleep quality among patients treated with implantable atrial defibrillation therapy: effect of nocturnal shock delivery and psychological distress. J Cardiovasc Electrophysiol. 2003;14(9):960-64. [pmid: 12950541].
119 Thomas SA, Friedmann E, Gottlieb SS, et al. Changes in psychosocial distress in outpatients with heart failure with implantable cardioverter defibrillators. Heart Lung. 2009;38(2):109-20. [pmid: 19254629].
120 Van den Broek KC, Nyklicek I, Van der Voort PH, et al. Shocks, personality, and anxiety in patients with an implantable defibrillator. Pacing Clin Electrophysiol. 2008;31(7):850-57. [pmid: 18684282].
121 Van Den Broek KC, Nyklicek I, Denollet J. Anxiety predicts poor perceived health in patients with an implantable defibrillator. Psychosomatics. 2009;50(5):483-92. [pmid: 19855034].
122 Pauli P, Wiedemann G, Dengler W, et al. A priori expectancy bias and its relation to shock experience and anxiety: a naturalistic study in patients with an automatic implantable cardioverter defibrillator. J Behav Ther Exp Psychiatry. 2001;32(3):159-71. [pmid: 11934128].
123 Petrucci R, Kushon D, Inkles R, et al. Cardiac ventricular support: considerations for psychiatry. Psychosomatics. 1999;40(4):298-303. [pmid: 10402874].
124 Undavia M, Goldstein NE, Cohen P, et al. Impact of implantable cardioverter-defibrillator recalls on patients' anxiety, depression, and quality of life. Pacing Clin Electrophysiol. 2008;31(11):1411-8. [pmid: 18950298].
125 Pedersen SS, Spinder H, Erdman RAM, et al. Poor perceived social support in implantable cardioverter defibrillator (ICD) patients and their partners: cross-validation of the multidimensional scale of perceived social support. Psychosomatics. 2009;50(5):461-67. [pmid: 19855031].
126 Chamberlain A. A pilot study of: the psychological effects post Implantable Cardioverter Defibrillators (ICD) surgery: exploring the effects on a veteran population [dissertation]. Palo Alto (CA). Pacific Graduate School Of Psychology. 2008.
127 Crossmann A, Pauli P, Dengler W, et al. Stability and cause of anxiety in patients with an implantable cardioverter-defibrillator: a longitudinal two-year follow-up. Heart Lung. 2007;36(2):87-95. [pmid: 17362789].
128 Crow SJ, Collins J, Justic M, et al. Psychopathology following cardioverter defibrillator implantation. Psychosomatics. 1998;39(4):305-10. [pmid: 9691699].
129 Dougherty CM, Thompson EA. Intimate partner physical and mental health after sudden cardiac arrest and receipt of an implantable cardioverter defibrillator. Res Nurs Health. 2009;32(4):432-42. [pmid: 19434648].
130 Fritzsche K, Forster F, Schweickhardt A, et al. Depressive coping is a predictor for emotional distress and poor quality of life in a German-Austrian sample of cardioverter-defibrillator implant recipients at 3 months and 1 year after implantation. Gen Hosp Psychiat. 2007;29(6):526-36. [pmid: 18022046].
131 Pedersen SS, Theuns DA, Jordaens L, et al. Course of anxiety and device-related concerns in implantable cardioverter defibrillator patients the first year post implantation. Europace. 2010;12(8):1119-26. [pmid: 20507853].
132 Van Den Broek KC, Denollet J, Nyklicek I, et al. Psychological reaction to potential malfunctioning of implantable defibrillators. Pacing Clin Electrophysiol. 2006;29(9):953-56. [pmid: 16981918].
133 Wheeler EC, Pretzer-Aboff I, Hardie T, et al. Psychological impact of implantable cardioverter defibrillator on their recipients. Dimens Crit Care Nurs. 2009;28(4):176-81. [pmid: 19546727].
134 Pedersen SS, Spindler H, Johansen JB, et al. Clustering of poor device acceptance and type D personality is associated with increased distress in Danish cardioverter-defibrillator patients. Pacing Clin Electrophysiol. 2009;32(1):29-36. [pmid: 19140910].
135 Pedersen SS, van Domburg RT, Theuns DA, et al. Concerns about the implantable cardioverter defibrillator: a determinant of anxiety and depressive symptoms independent of experienced shocks. Am Heart J. 2005;149(4):664-9. [pmid: 15990750].
136 Sowell LV, Sears SF, Walker RL, et al. Anxiety and marital adjustment in patients with implantable cardioverter defibrillator and their spouses. J Cardiopulm Rehabil Prev. 2007;27(1):46-49. [pmid: 17474644].
137 Spindler H, Johansen JB, Andersen K, et al. Gender differences in anxiety and concerns about the cardioverter defibrillator. Pacing Clin Electrophysiol. 2009;32(5):614-21. [pmid: 19422582].
138 Craney JM, Mandle CL, Munro BH, et al. Implantable cardioverter defibrillators: physical and psychosocial outcomes. Am J Crit Care. 1997;6(6):445-51. [pmid: 9354222].
139 Fisher JD, Koulogiannis KP, Lewallen L, et al. The psychological impact of implantable cardioverter-defibrillator recalls and the durable positive effects of counseling. Pacing Clin Electrophysiol. 2009;32(8):1012-16. [pmid: 19659621].
140 Frizelle DJ, Lewin B, Kaye G, et al. Development of a measure of the concerns held by people with implanted cardioverter defibrillators: the ICDC. Br J Health Psychol. 2006;11:293-301. [pmid: 16643700].
141 Zigmond AS, Snaith RP. The Hospital Anxiety and Depression Scale. Acta Psychiatr Scand. 1983;67:361-70. [pmid: 6880820].
142 Spielberger CD, Grambow SC, Machado C, et al. Manual for the state-trait anxiety inventory. Palo Alto (CA). Consulting Psychologists Press. 1983.
143 Muthny FA. FKV Freiburger Fragebogen zur Krankheitsverabeitung (FQCI-Freiburg Questionnaire of Coping with Illness). Beltz. Weinheim. 1989.
144 Burns JL, Serber ER, Keim S, et al. Measuring patient acceptance of implantable cardiaz device therapy: Initial psychometric investigation of the Florida Patient Acceptance Survey. J Cardiovasc Electrophysiol. 2005;16:384-90. [pmid: 15828880].
145 Ware JE, Snow KK, Kosinski M, et al. SF-36 Health Survey: manual and interpretation guide. Boston (MA). The Health Institute, New England Medical Centre. 1993.
146 Denollet J. DS14: Standard assessment of negative affectivity, social inhibition, and Type D personality. Psychosom Med. 2005;67:89-97. [pmid: 15673629].
147 Cladwell PH, Arthur HM, Demers C. Preferences of patients with heart failure for prognosis communication. Can J Cardiol. 2007;23(10):791-96. [pmid: 17703257].
148 Serber ER, Finch NJ, Leman RB, et al. Disparities in preferences for receiving support and education among patients with implantable cardioverter defibrillators. Pacing Clin Electrophysiol. 2009;32(3):383-90. [pmid: 19272070].
149 Stutts LA, Conti JB, Aranda JM, et al. Patient evaluation of ICD recall communication strategies: a vignette study. Pacing Clin Electrophysiol. 2007;30(9):1105-11. [pmid: 17725753].
150 Sherazi S, Zareba W, Daubert JP, et al. Physicians' knowledge and attitudes regarding implantable cardioverter-defibrillators. Cardiol J. 2010;17(3):267-73. [pmid: 20535717].
151 Clark AM, Freydberg N, McAlister FA, et al. Patient and informal caregivers' knowledge of heart failure: necessary but insufficient for effective self care. Eur J Heart Fail. 2009;11(6):617-21. [pmid: 19414477].
152 Horowitz CR, Rein SB, Leventhal H. A story of maladies, misconceptions and mishaps: Effective management of heart failure. Soc Sci Med. 2004;58(3):631-43. [pmid: 14652059].
153 Riegel B, Dickson VA. A situation-specific theory of heart failure self care. J Cardiovasc Nurs. 2008;23:190-96. [pmid: 18437059].
154 Linden W. Psychological treatments in cardiac rehabilitation: review of rationales and outcomes. J Psychosom Res. 2000;48:443-54. [pmid: 10880665].
155 Rutledge T, Reis V, Linke S, et al. Depression in heart failure: a meta-analytic review of prevalence, intervention effects, and associations with clinical outcomes. J Am Coll Cardiol. 2006;48:1527-37. [pmid: 17045884].
156 American Medical Association. H–140.966 Decisions Near the End of Life. [cited 2011July 4]. Available from: https://ssl3.ama-assn.org/apps/ecomm/PolicyFinderForm.pl?site=www.ama-assn.org&uri=%2fresources%2fdoc%2fPolicyFinder%2fpolicyfiles%2fHnE%2fH-140.966.HTM.
157 Implantable cardioverter defibrillators in patients who are reaching the end of life. London. British Heart Foundation. 2007. [cited 2011 July 4]. Available from: http://www.bsh.org.uk/portals/2/icd%20leaflet.pdf.
158 Tzeis S, Andrikopoulos G, Kolb C, et al. Tools and strategies for the reduction of inappropriate implantable cardioverter defibrillator shocks. Europace. 2008;10:1256-65. [pmid: 18708639].
159 Wilkoff BL, Auricchio A, Brugada J, et al. HRS/EHRA expert consensus on the monitoring of cardiovascular implantable electronic devices (CIEDs): description of techniques, indications, personnel, frequency and ethical considerations. Heart Rhythm. 2008;5(6):907-25. [pmid: 18551743].
160 Salmoirago-Blotch E, Ockene IS. Methodological limitations of psychosocial interventions in patients with implantable cardioverter-defibrillator (ICD): a systematic review. BMC Cardiovasc Disord. 2009;9:56. [pmid: 20040100].
161 Freedenberg V, Thomas SA, Friedmann E. Anxiety and depression in implanted cardioverter-defibrillator recipients and heart failure: a review. Heart Fail Clin. 2011;11:59-68. [pmid: 21109208].
162 Sears SF, Vazquez LD, Matchett M, et al. State-of-the-art: anxiety management in patients with implantable cardioverter defibrillators. Stress and Health. 2008;24(3):239-48.
163 Neubeck L, Redfern J, Fernandez R, et al. Telehealth interventions for the secondary prevention of coronary heart disease: a systematic review. Eur J Cardiovasc Prev Rehabil. 2009;16(3):281-9. [pmid: 19407659].
164 Dalal HM, Zawada A, Jolly K, et al. Home-based versus centre based cardiac rehabiltiation: Cochrane systematic review and meta-analysis. BMJ. 2010;340:b5631. [pmid: 20085991].
165 Clark AM. Home-based cardiac rehabilitation. BMJ. 2010;340:b5510. [pmid: 20085990].
166 Clark AM, Haykowsky M, Kryworuchko J, et al. A meta-analysis of randomized control trials of home-based secondary prevention programs for coronary artery disease. Eur J Cardiovasc Prev Rehabil. 2010;17(3):261-70. [pmid: 20560165].