# Methods

The Center for Medicare Management Group at the Centers for Medicare and Medicaid Services requested this report from the Technology Assessment Program at the Agency for Healthcare Research and Quality (AHRQ). AHRQ assigned this report to the University of Alberta Evidence-based Practice Center.

This chapter describes the prospectively designed methods that the University of Alberta Evidence-based Practice Center used to identify, assess, and synthesize the evidence on electronic cardiac devices (ECDs) in relation to the key questions (KQs). We outline the literature search strategy and our approach to selecting relevant articles, extracting data from eligible studies, assessing the methodological quality of individual studies and rating the overall body of evidence, and analyzing and synthesizing the data.

## Literature Search

The research librarian, in collaboration with the research team, developed search strategies designed to identify evidence relevant to the KQs. Our search for the published literature included structured searches in the following bibliographic databases: MEDLINE^®^ (1948–2011), EMBASE (1980–2011), CINAHL (1980–2011), Cochrane Central Register of Controlled Trials, SCOPUS, and PsycINFO (1903–2011). The searches were performed between December 8, 2010 and Feb 8, 2011. Search terms were identified through consultation with research team members, reviewing search strategies from systematic reviews on similar topics, and examining how relevant studies had been indexed in various databases. A combination of subject headings and text words was adapted for each database.

We completed two sets of searches for published literature (Appendix A). First, we conducted a broad search using a combination of the following terms: (pacemaker* OR heart-assist device* OR ICD or CIED OR implantable defibrillator* ) AND ((decision making or choice behavio?r OR patient preference* OR communication* OR consent* OR proxy OR decision aid* OR decision tool* OR decision support* OR gender OR health knowledge OR patient attitude* OR treatment refusal OR treatment withdrawal OR device removal OR deactivation OR palliative care OR hospice care OR terminal care OR end-of-life). We restricted searches to English language studies published after 1989. We applied study design filters to capture experimental and qualitative studies.

This search was supplemented by a second search in order to elicit additional articles published after the first search or articles that may have been missed (Appendix A). The second search focused on the concepts of ECDs and end-of-life; the qualitative design filter was not applied. Search terms included: (pacemaker* OR heart-assist device* OR ICD or CIED OR implantable defibrillator*) AND (treatment refusal OR treatment withdrawal OR device removal OR deactivation OR palliative care OR hospice care OR terminal care OR end-of-life).

To locate grey literature, we searched Google using combinations of keyword terms for ECDs and end-of-life decisionmaking. Results from these searches were stored and categorized in a bookmarking web software called Delicious (www.delicious.com) and were evaluated by the by the research team for potential relevancy to KQ 1 to 4. In addition to searching online resources, we hand searched reference lists from relevant publications and included studies, consulted with content experts, and searched citations.

## Study Selection

We developed a priori eligibility criteria for each KQ, which are described below. Two reviewers independently screened the titles and abstracts of the search results using broad criteria. We classified each study as “include,” “exclude,” or “unsure.” We retrieved the full text articles for all studies that were rated “include” or “unsure.” Two reviewers independently reviewed the full text of potentially relevant studies using a standard form that was pretested on a sample of studies. We resolved disagreements through consensus or third-party arbitration.

### KQs 1 to 3 Decision Aids and Tools

To be eligible for inclusion for KQ 1–3, studies must have examined any decision aid or tool in adult patients with or needing an ECD, regardless of age or condition. ECDs included implantable cardioverter defibrillators (ICDs), cardiac resynchronization therapy plus ICDs (CRT–ICDs), pacemakers, and ventricular assist devices (VADs). We defined decisionmaking tools according to the International Patient Decision Aid Standards Collaboration definition as: “…tools designed to help people participate in decisionmaking about health care options. They provide information on the options and help patients clarify and communicate the personal value they associate with different features of the options.”66 We did not prespecify outcomes.

Initially, we included only comparative studies, such as randomized controlled trials (RCTs), cluster RCTs, nonrandomized controlled trial (NRCT), pragmatic trials (e.g., trials comparing tools), and quasi-experimental pre-post test studies. However, our initial searches did not identify any tools that had been evaluated in trials or other comparative studies. Therefore, we made a post hoc decision to include qualitative and uncontrolled studies.

### KQ 4 Barriers to Decision Aids and Tools

To be included in KQ4, studies had to contain primary data that could be reasonably interpreted as pertaining to barriers (or conversely, facilitators) to the use of decision tools or similar aids in relation to ECDs in eligible patients. We did not prespecify methodological criteria. As such, studies could use qualitative, survey, other observational methods, or mixed methods.

## Methodological Quality

We assessed the methodological quality of the included studies and decision aids using a variety of tools, depending on the KQ being addressed and study design.

### KQs 1 to 3 Decision Aids and Tools

We planned to use the Cochrane Risk of Bias tool to assess RCTs and NRCTs;67 however, we did not identify any eligible trials.

To assess the quality of the decision tools, we used a previously validated, systematic assessment framework for decision aids.68 This framework assesses quality in all stages of tool development (including: processes of refinement and final content) and multiple facets of a tool, including the following domains: systematizing the development process; providing information about treatment options; presenting probabilities; clarifying and expressing values; using patient stories; guiding and coaching; disclosing conflicts of interest; providing internet access; balancing presentation of options; using plain language; basing information on up-to-date evidence; and establishing effectiveness. Two reviewers independently appraised the decision aids, and there were no discrepancies in their assessments.

### KQ 4 Barriers to Decision Aids and Tools

We used different tools to assess the methodological quality of studies depending on study design. For qualitative studies, we used the Critical Appraisal Skills Program tool for assessing qualitative research.69 This narrative-based tool can be used for different qualitative methods and has been previously validated in large qualitative systematic reviews.70 For observational studies, we used a tool for cohort studies71 and for descriptive cross-sectional studies.72 We categorized studies as being of high, medium, or low quality.

One reviewer applied the tools, and a second reviewer independently checked the appraisal. We resolved differences in quality assessments by consensus.

## Data Extraction

One reviewer extracted data from individual studies using standardized templates; a second reviewer independently verified the data for accuracy and completeness.

### KQ 1 to 3 Decision Aids and Tools

We extracted information on the content of each tool and its development using the content of the tools and the fields of the systematic assessment framework for decision aids.68(Appendix C)

### KQ 4 Barriers to Decision Aids and Tools

We classified studies into three categories: a) qualitative studies describing general experiences with ECDs; b) quantitative studies addressing psychosocial outcomes; and c) mixed method studies relating to communication.

We used different data extraction forms for studies using qualitative and quantitative designs, which are available in Appendix B. Data were extracted on elements of tools. For qualitative and mixed method studies, we extracted publication details (year, author, study title, journal, main focus of paper), methodological details (principle approach, data collection methods, sampling methods), and population characteristics (sex, age, recruitment criteria, country of study, device type). We noted if the participants were patients, health professionals, or caregivers. When possible, we recorded details regarding indication for ECD (primary or secondary prevention), New York Heart Association functional class, left ventricular ejection fraction, and disease (heart failure or non-heart failure). We also recorded the focus of the study in relation to ECD insertion, malfunction, deactivation, or end-of-life.

For quantitative studies focusing on psychosocial outcomes, we similarly extracted publication details, population characteristics, and the indication for ECD (primary or secondary prevention). We noted if the participants were patients, spouses, or other primary caregivers. We recorded which instruments were used to measure specific outcomes. For each outcome, we extracted baseline, followup, and change from baseline data, including information on the effect size and statistical significance, if available.

## Data Synthesis

### KQ 1 to 3 Decision Aids and Tools

We present a narrative summary of the studies that provided data to address this question.

### KQ 4 Barriers to Decision Aids and Tools

For qualitative studies on general experiences with ECDs, we used a meta-ethnographic approach to synthesise findings.73,74 This approach provides a new synthesis of findings to account for the phenomenon being explored74 and involves a three-stage process including first-order findings, second-order interpretations, and higher-order abstractions. Through this process, studies are re-analyzed and compared in light of each other to produce new theory or knowledge (Table 3).74,75

Table 3 Stages of synthesis of qualitative studies

Synthesis Stage | Description | Output
1. First-order findings | Each primary reviewer read each study to identify, based on the team's definition of help seeking, the main concepts in each study linked to help seeking decisions and experiences. First-order findings were recorded in a matrix with study details and methodological quality results. | A detailed description of the findings of each study.
2. Second-order interpretations | Each primary reviewer independently examined the nature and relationships between concepts identified in Stage 1. Views of main themes across studies were discussed at length. Common or reoccurring concepts or those that provided explanations for help seeking were sought and interpreted in the context of study quality and setting. Main concepts identified at this stage were: the problematic nature of cardiac heart failure, the ambiguity of body sensations, links with wider self-care, help seeking processes, and coping. | Interpretations of common or reoccurring concepts or those that provided explanations for help seeking.
3. Higher-order abstractions | The main concepts identified during Stage 2 were re-interpreted in the light of the findings on help seeking from each paper. A line of argument or explanatory interpretation was developed in an iterative process to identify and question key barriers and facilitators of help-seeking. | The research synthesis presented in this paper.

We used an integrative approach to synthesis for the quantitative studies related to psychosocial barriers to tool use in the ECD population. We chose this approach because, although the selected studies were on the same topic, there were differences in methods and outcomes which precluded pooling of results.76 For the integrative review, we examined the findings of comparable studies in relation to each other, taking account of the methodological quality and differences in populations.76

For mixed methods studies on communication, we followed the same steps for quantitative studies of psychosocial outcomes.76