# Introduction

Emerging technologies raise new challenges in health care and for health care professionals. Over the past three decades, electronic cardiac devices (ECDs) have been used to electronically stimulate the heart. These devices include:

- Implantable cardioverter-defibrillators (ICDs), including those with cardiac resynchronization therapy functions (CRT–ICDs);
- Pacemakers; and
- Ventricular assist devices (VADs).

Medicare coverage criteria for ICDs have been considerably broadened in the past 5 years.1 In the United States, 68 percent of patients with an ICD implantation are Medicare beneficiaries, and the average age at implantation is 68 years.2

Professionals have expressed reservations about over-insertion of ECDs, most notably in relation to ICDs3-5 and the relative size of clinical benefits and harms of such devices.6,7 Patients with ICDs may develop terminal illnesses as a result of worsening of their underlying heart condition or other chronic disease. Terminally-ill patients are at greater risk for developing hypoxia, sepsis, heart failure, and electrolyte imbalance, which predisposes them to arrhythmias and thereby increases the frequency of ICD shocks. The ICD discharges (‘shocks’) may be so painful and frequent that the harms derived from an ICD can outweigh the benefits.8 Therefore, it is reasonable to consider deactivating the ICD to neutralize the harm from the device as a patient nears the end of life.

## Ethical and Legal Considerations

In the United States, mainstream media has raised concerns over the lack of patient involvement in health care decisions near the end of life.9-11 Most prominently, these issues have been expressed about ECDs in relation to informed consent and decisions to deactivate ICDs near the end of life.1 Indeed, a series of papers published before 2006 expressed concerns that withdrawal of ICDs and other ECDs may be unethical or even illegal in some circumstances.12-14 A recent survey of legal and medical professionals and patients indicated that the majority believe it is lawful to withdraw device therapy at the end of life in response to a patient's request;15 however, almost half of the U.S. physicians surveyed in 2008 were unsure of the legality of deactivating an ICD.16 Guidelines in the United States17 recommend that it can be appropriate to reprogram the device, deactivating the patient's ICD, near the end of life.

### Informed Consent

Concerns about the quality of informed consent have been raised regarding ICDs,18-20 pacemakers,21 and VADs.22-24 Ensuring ongoing informed consent is as important as addressing the clinical effects of insertion or deactivation in each patient.25 Health care decisions should address the likely benefits, harms, and costs of an intervention for the particular patient, but also its ethical and legal appropriateness and congruence with the patient's values and preferences.25-27

Informed consent is recognized internationally as being essential to health care and is based on the key ethical and legal principles highlighted in Table 1.^28,29^ For decisions to be based on informed consent, they must be made voluntarily by patients who have the legal standing and sufficient capacity to make decisions.30 Decisions should be based on the provision of sufficient accurate information for patients to understand the choices being made, the likely benefits, and any common and serious potential harms of an alternative course of action.30 Further, this information should be specific to the patient's personal situation.30 These principles serve to respect patient autonomy, protect the patient from fraud, misinformation, and coercion under duress, and promote self-reflection and rational decisionmaking by health professionals.31

Table 1 Key components of informed consent31

Component | Explanation
Voluntary | Decisions are made without coercion, inducement, or persuasion
Capacity | The deciding party(s) has the facets to make the decision
Legal standing | The deciding party(s) is legally the individual appropriate to make the decision
Disclosure | Provision of the right information to understand the proposed course of action and possible alternatives

Informed consent also addresses the legal authority upon which decisions are made: whether or not those involved in making a decision are legally entitled to participate.30 Operational issues include what documentation should be used to provide information and record consent, when consent should be sought, and who should seek consent from patients or surrogate decisionmakers.32

The American Medical Association (AMA) mandates that care should be based on informed consent and should incorporate the “clinical impression” of clinicians regarding consequences of treatment, alternatives, and recommendations for all procedures.33 The current AMA policy states that “full disclosure (is) appropriate in all cases, except in rare situations in which such information would, in the opinion of the health care professional, cause serious harm to the patient.”34

When patients do not have the capacity to make decisions, the health care team should honor an advanced directive to respect patient autonomy.34 When an advanced directive is not available, reasonable efforts should be taken to identify a prior written expression of values such as a pertinent living will or a health care proxy.34 When such materials are unavailable and there are no state laws identifying appropriate surrogate decisionmakers or a process to identify them, the patient's family, domestic partner, or close friend should become the surrogate decisionmaker.34 The AMA states that surrogate decisionmakers should be accorded the same rights as patients.34

### Principles to Guide Decisionmaking

Advice to support decisions around ICD deactivation for patients nearing the end of life or requesting withdrawal of therapy were recently addressed by the European Heart Rhythm Association8 and the U.S. Heart Rhythm Society (HRS).35 These guidelines do not view decisions about devices as different from other decisions pertaining to consent for the withdrawal or initiation of health care treatments or interventions. Hence, normal procedures associated with legal and ethical consent should be followed. Decisions about whether to insert or deactivate an ECD, like other decisions to initiate or withdraw treatment, have clear legal and ethical dimensions and require informed consent.

The HRS guidelines35 are based on the following key ethical, legal, and religious principles and precedents:

- A patient with decisionmaking capacity has the legal right to refuse or request the withdrawal of any medical treatment or intervention regardless of whether he or she is terminally ill, and regardless of whether the treatment prolongs life and its withdrawal results in death.
- When a patient lacks capacity, his or her legally-defined surrogate has the same right to refuse or request withdrawal.
- Ethically and legally, there are no differences between refusing ICD therapy and requesting a withdrawal of ICD therapy.
- Advanced directives should be encouraged for all patients with ICDs.
- Legally and ethically carrying out a request to withdraw life-sustaining treatment is neither physician-assisted suicide nor euthanasia.
- A health professional cannot be compelled to carry out ICD deactivation that he or she views is in conflict with their own personal values, but should involve a colleague who is willing to carry out the procedure.

The HRS guidelines also make clear that decisions may have spiritual and religious dimensions for the patient and health professionals involved in the decision.35 This concurs with the AMA guidelines that the values of the patient should be incorporated in the decisionmaking process.34 Although a clinician has the right not to perform the deactivation, the clinician's religious beliefs may not override those of the patient.35 However, deactivation is not incompatible with religious beliefs related to the preservation of life.36

These guidelines address concerns about the ethics of deactivation12-14 and physician reservations about the legal implications of withdrawing device-related care.18-20 These have remained for some years because of a lack of legal precedents.15,19 However, there is no indication from HRS guidelines,35 similar European guidelines,8 or from the AMA that deactivation of a device could be considered an illegal physician-assisted suicide or form of euthanasia.37,38 Likewise, ethical and legal issues around resuscitation address cardiopulmonary resuscitation after a cardiac or respiratory arrest not overtly ECDs.39 Nor are there any legal indications that the current HRS guidelines would not apply to other devices, notably VADs,22 or across all U.S. states.35 Guidelines mention options of partial deactivation of shocks or depletion of the device generator, but do not make an ethical distinction between partial and full deactivation. 35 Advanced directives, either in the form of a power of attorney to specify a surrogate decisionmaker or a list of health care preferences, values, or religious beliefs in a living will, are recognized across 50 states.35

The same ethical and legal principles related to ICD deactivation apply to the insertion and deactivation of other ECDs. Discussions about deactivating any ECD should follow best practices of informed consent, but are not subject to any distinctive legal or ethical requirements.23 Issues in relation to pacemakers near the end of life may be less likely to arise because these devices rarely cause harmful or painful shocks compared to ICDs and do not lengthen life.19 VADs may become burdensome for patients and their caregivers near the end of life due to the need to assess and monitor device function23 and in relation to patient anxiety.22

### Ethical and Legal Care Processes

Although past arguments questioning the ethics of deactivation12-14 now appear to be out of step with current guidelines and consensus, dismissing these concerns is inappropriate.40 Crucially, ensuring decisions about deactivation are legal and ethical is dependent on key processes of care associated with seeking and attaining informed consent.12-14,41 Concerns about the ethical and legal aspects of deactivation appear well placed when current practices around patient-professional communication, the complexity of care, and aspects of organizational context are taken into account.

For ICDs while current recommendations indicate that the primary caring physician should broach deactivation initially, but if deactivation conflicts with the clinician's conscience, the physician should attempt to identify another clinician to deactivate.35 When this is not possible an administrator or ethics board can be involved providing the physician's relationship continues with the patient and clinicians have expressed their abstinence in a value free manner.35 It should also be recognized that other health professionals may broach discussions with health professionals or experience concern or distress around deactivation.

#### Communication and Consent

Evidence shows that communication between patients, surrogate decisionmakers, and health professionals regarding the deactivation of ICDs is often poor. In a telephone survey, the next-of-kin of dying patients reported that physicians discussed deactivating the ICD in only 27 percent of cases.42 A recent survey of 47 European care centers showed that only 4 percent reported routinely discussing deactivation with patients at or before insertion, and 4 percent provided patients and surrogate decisionmakers with information on deactivation.43 Communication around deactivation often takes place only days or even hours before the patient's death.42 Only 33 percent of internists and 45 percent of cardiologists thought their patients were aware that ICDs could be deactivated.44 Ambulant patients with ICDs reported that discussions about deactivation rarely occurred during the course of their care45-47 and expressed a desire for these discussions to take place earlier.47 A systematic review showed that patients are anxious about future shocks and have limited knowledge of ICDs.48

The HRS guidelines35 (Table 2) emphasize the importance of initiating dialogue prior to ICD insertion and continuing dialogue throughout the care trajectory. Discussions should be timely,29,49 occur before the end-of-life phase,29,49 and address misconceptions that deactivation may result in immediate death.50 Patients should receive information about the option to deactivate an ICD prior to potential loss of functional capacity; when anti-arrhythmic drug therapy is withdrawn; when a patient's heart failure status changes; and at refractory end-stage heart failure.17,49 For the Medicare population, physicians should discuss the impact of decisions on comorbidities and general health status and recommend specialist geriatric consultations to maximize patient involvement.35

Table 2 Recommendations for Communicating about Deactivation (HRS 2010)35

Aim(s) | Key questions for patients or surrogate decisionmakers
1. Determine what patients/families know about their illness. | “What do you understand about your health and what is occurring in terms of your illness?”
2. Determine what patients/families know about the role the device plays in their health both now and in the future. | “What do you understand about the role of the [cardiac device] in your health now?”
3. Determine what additional information patients/families want to know about their illness. | “What else would be helpful for you to know about your illness or the role the [cardiac device] plays in it?”
4. Correct or clarify any misunderstandings about the current illness and possible outcomes, including the role of the device. | “I think you have a pretty good understanding of what is happening in terms of your health, but there are a few things I would like to clarify with you.”
5. Determine the patient/family's overall goals of care and desired outcomes. | “Given what we've discussed about your health and the potential outcomes of your illness, tell me what you want from your health care at this point.” For patients or families needing more guidance: “At this point some patients tell me they want to live as long as possible, regardless of the outcome whereas other patients tell me that the goal is to be as comfortable as long as possible while also being able to interact with their family. Do you have a sense of what you want at this point?”
6. Using the stated goals as a guide, work to tailor treatments, and in this case, management of the cardiac device to those goals. Phrases to be used here depend on the goals as set by the patient and family. | 1) For a patient who states that her desired goal is to live as comfortably as possible for whatever remaining time she has left: “Given what you've said about assuring that you are as comfortable as possible, it might make sense to deactivate the shocking function of your ICD. What do you think about that?” OR 2) For a patient who states s/he wants all life-sustaining treatments to be continued, an appropriate response might be, “In that case, perhaps leaving the anti-arrhythmia function of the device active would be most in line with your goals. However, you should understand that this may cause you and your family discomfort at the end of life. We can make a decision at a future point in time about if/when to deactivate.”

#### Complexity

A principle reason for challenges around communication, consent, and decisionmaking in relation to devices is the complexity of decisionmaking, particularly in relation to the likelihood of future events particularly near the end of life. Although the decision to deactivate an ECD can be viewed in some respects as the same as other decisions about treatment withdrawal or intervention,35 additional uncertainties exist related to deactivation (versus retaining the fully functioning ICD in place), particularly pertaining to the future likely course of the patient's progression around prognosis and the likelihood of shocks near the end of life should the patient not choose deactivation.

As with the decision to insert a device, health professionals must also use clinical judgment to assess the evidence concerning the size of the future potential benefits for retaining a fully functioning ICD for the specific patient.7,51 However, estimating the size of this future benefit from existing trials is challenging because data on risk reduction are derived from trials with broad enrollment criteria and patients who are not near the end of life.52 For some groups of patients, the actual benefit of retaining the ICD in place may be much smaller than current trials suggest and might be borderline at best for some clinical subpopulations.7 Compounding this, even during the end-of-life stage, the patient's anticipated life expectancy is also very difficult to predict,24,42,47,53 and most sudden cardiac deaths still occur in patients who are assessed as being at low or medium levels of risk.54,55 Furthermore, current tools to assess the risk of sudden cardiac death have limited predictive power.56,57 As such, decisions relating to deactivation near the end of life are subject to multiple ambiguities that extend far beyond “uncertainties.”

#### Context

The ethics and legality of informed consent are also compounded by a lack of institutional support for care and a lack of adequate training in clinicians. Discussions about deactivation are complex for health professionals because of multiple uncertainties related to expected prognosis in cardiac patients42 and the anticipated frequency of shocks (whether necessary or unnecessary) a patient will receive.44 Moreover, this dialogue often occurs when the health professional has had little prior relationship with the patient.46 Some have questioned whether health professionals, particularly cardiologists, are trained adequately to deal with such issues.21 Health professionals who have had problematic prior experiences discussing deactivation with patients are less likely to broach the topic in subsequent discussions with other patients.58 Although health professionals are often aware that patients have concerns about dealing with ICD shocks, some are still not comfortable discussing deactivation issues.59 Health professionals may also be wary of instigating discussions about deactivation with patients because of legal concerns around whether deactivation of an ICD could be interpreted as a withdrawal of treatment19 or cited as a cause of death.60

Health professionals may be concerned about a lack of institutional support and advice around deactivation. A recent survey of 900 U.S. hospices indicated that although 97 percent had admitted patients with ICDs (58 percent reported that patients had received shocks, and 42 percent reported deactivation of devices in the past), only 10 percent had policies on deactivation (95% CI, 37 percent to 48 percent).61 Health professionals have also reported higher levels of discomfort in relation to deactivation of pacemakers; 60,62 around one-third of those surveyed in the United States reported being comfortable deactivating a pacemaker in a terminally-ill patient compared with over 56 percent in relation to ICDs (p<0.001).

## Decisionmaking Tools: A Potential Solution?

Guidelines are essential tools for promoting evidenced-based care. In the case of ECDs, they provide an important means to ensure that care is ethical and legal. As with other health care decisions, there is no inherent “best choice” around whether to deactivate an ECD.63 Decisions about ECD deactivation are complex, value-laden, and deal with wide ranging probabilities and uncertainty.64 These decisions may involve patients and next-of-kin who may have limited understanding or unrealistic expectations of ECDs65 and health professionals who may not understand the knowledge levels, values, and aspirations of the patient and next-of-kin and may struggle to translate population-based risks to individuals.65

Patient decision aids have been developed to help health professionals support patients and next-of-kin in making informed decisions about health care treatments.64 Patient decision aids support decision quality and reduce unwanted variations in practice by:

- Providing factual information about the patient's condition, options, outcomes, and probabilities;
- Detailing patients' evaluations of the outcomes that matter most to them; and
- Guiding patients in the steps of deliberation and communication so the choice taken best accords with their values.65

The aids can be administered to groups of patients or on an individual basis and via face-to-face, print, or electronic means (e.g., web, video, or App).65 Decision aids facilitate understanding of the decision and better ensure decisions that are in accord with the values, preferences, and circumstances of patients and next-of-kin.64 Indeed, these aids are more effective at ensuring higher “quality” decisions than standard forms of counseling.65 In a recent Cochrane systematic review of 55 trials,63 decision aids were found to significantly improve knowledge, lower decisional conflict related to feeling uninformed or unclear about personal values, and reduce the proportion of people who were passive in decisionmaking or remained undecided post-intervention.63 These decision aids also: a) can be incorporated into care systems and protocols64 (thereby addressing health professional avoidance, discomfort, and lack of timeliness of discussions); b) are systematic (thereby addressing the inconsistencies in current discussion practices); c) take account of values relating to benefits and harms64 (thereby addressing some key elements of deactivation decisions); and, d) address patient and next-of-kin understanding and knowledge levels (thereby addressing common knowledge limitations).

Decisions aids do not constitute clinical guidelines for health care around specific decisions, but can incorporate the recommendations from guidelines more systematically into the dialogue, discussions, and decisions necessary for informed consent. Given the evidence suggesting that discussion around deactivation of devices is often poorly addressed in health care practice, decision aids appear to offer potential to support effective, ethical, and legal decisionmaking around the deactivation of ECDs. That said, effect sizes tend to vary widely across studies and populations, and there is limited application to patients with heart disease.63

## Objectives and Key Questions

The objectives of this report are to identify and synthesize the available evidence regarding decisionmaking aids and similar tools for ECDs, determine the generalizabililty of these tools to the Medicare population, and identify the main barriers to the use of such tools in the future to patient populations.

We examined the following key questions (KQs) for patients undergoing insertion, continuation, or deactivation of ECDs (including pacemakers, ICDs and CRT–ICDs, and VADs) and their next-of-kin:

1. Are there validated decision aids and tools available for ECDs?
2. How effective are these decision aids and similar tools for promoting informed decisionmaking?
3. Is the Medicare population sufficiently represented in the published studies? If not, are the conclusions of the studies generalizable to the Medicare population?
4. What are the main barriers to the use of decision aids?