# Executive Summary

## Background

Over the past three decades, electronic cardiac devices (ECDs) have been used to electronically stimulate the heart in order to regulate heart function. ECDs include implantable cardioverter-defibrillators (ICDs; with or without cardiac resynchronization therapy [CRT] function), pacemakers, and ventricular assist devices (VADs).

Patients with ECDs may develop terminal illnesses due to worsening of their underlying heart condition or other chronic disease. Terminally-ill patients are at greater risk for developing tachyarrhythmias and other arrhythmias, thereby increasing the frequency of ICD shocks. ICD discharges may be so painful and frequent that the harms derived from an ICD can outweigh the benefits.1 Therefore, it is reasonable to consider deactivating the shock function of the ICD to neutralize harm from the device as a patient nears the end of life.

This is challenging however because of the complexity of decisionmaking, particularly in relation to end-of-life issues which are charged with multiple uncertainties around the effects of deactivation, prognosis, and possible frequency of shocks.

High-quality decisionmaking, with associated aspects such as informed consent, effective communication, and patient involvement, has emerged as an important area for the insertion and deactivation of ECDs. Recently, the Health Rhythm Society in the United States has addressed important ethical and legal concerns regarding deactivating ICDs and published guidelines on how to promote effective and ethical decisionmaking. These and other recent European guidelines view deactivation of devices as being similar in ethical and legal terms as the withdrawal of any other form of health care or medical treatment. Current opinion is that deactivation of ICDs cannot be considered legally or ethically synonymous with any form of assisted suicide, euthanasia, or cardiopulmonary resuscitation.

For practice to be ethical, informed consent must guide decisionmaking on the withdrawal of devices. Specific recommendations exist for ICDs, with current guidelines stating that deactivation issues should be discussed prior to insertion. Further, decisions should be made wherever possible by patients following extensive dialogue with appropriate physician(s) and should be based on personalized, balanced, and comprehensive information of choices. Sufficient time should be provided for patients to make decisions and when possible, discussions should occur prior to the end-of-life stages of the underlying disease.

However, over the past five years, evidence has consistently shown that health care practices around decisionmaking in the United States and elsewhere remain concerning and frequently risk compromising informed consent, particularly in relation to ICDs. Decisionmaking aids have been found to be effective in promoting shared and effective decisionmaking in various populations and health decisions. We then examine here the possible effectiveness of these aids in relation to the insertion, continuation, or cessation of ICDs.

## Objectives and Key Questions

The objectives of this report were to: identify and synthesize the available evidence regarding decisionmaking aids and similar tools for ECDs; determine the generalizabililty of these tools to Medicare populations; and identify the main barriers to the use of such tools.

The key questions (KQs) were as follows: For patients undergoing insertion, continuation, or deactivation of ECDs (including pacemakers, ICDs and CRT–ICDs, and VADs) and their next-of-kin:

1. Are there validated decision aids and tools available for ECDs?
2. How effective are these decision aids and similar tools for promoting informed decisionmaking?
3. Is the Medicare population sufficiently represented in the published studies? If not, are the conclusions of the studies generalizable to the Medicare population?
4. What are the main barriers to the use of decision aids?

## Methods

### Literature Search

The research librarian, in collaboration with the research team, developed search strategies designed to identify evidence relevant to the KQs. Our search for the published literature included structured searches in the following bibliographic databases: MEDLINE^®^ (1948–2011), EMBASE (1980–2011), CINAHL (1980–2011), Cochrane Central Register of Controlled Trials, SCOPUS, and PsycINFO (1903–2011). The searches were performed between December 8, 2010 and February 8, 2011. We identified search terms through consultation with research team members, reviewing search strategies from systematic reviews on similar topics, and examining how relevant studies had been indexed in various databases. A combination of subject headings and text words was adapted for each database.

We completed two sets of searches for published literature (Appendix A). First, we conducted a broad search using a combination of the following terms: (pacemaker* OR heart-assist device* OR ICD or CIED OR implantable defibrillator* ) AND ((decision making or choice behavio?r OR patient preference* OR communication* OR consent* OR proxy OR decision aid* OR decision tool* OR decision support* OR gender OR health knowledge OR patient attitude* OR treatment refusal OR treatment withdrawal OR device removal OR deactivation OR palliative care OR hospice care OR terminal care OR end-of-life). We restricted searches to English language studies published after 1989. We applied study design filters to capture experimental and qualitative studies.

This search was supplemented by a second search in order to elicit additional articles published after the first search or articles that may have been missed (Appendix A). The second search focused on the concepts of ECDs and end-of-life; the qualitative design filter was not applied. Search terms included: (pacemaker* OR heart-assist device* OR ICD or CIED OR implantable defibrillator*) AND (treatment refusal OR treatment withdrawal OR device removal OR deactivation OR palliative care OR hospice care OR terminal care OR end-of-life).

To locate grey literature, we searched Google using combinations of keyword terms for ECDs and end-of-life decisionmaking. Results from these searches were stored and categorized in a bookmarking web software called Delicious (www.delicious.com) and were evaluated by the research team for potential relevancy to KQ 1 to 4. In addition to searching online resources, we hand searched reference lists from relevant publications and included studies, consulted with content experts, and searched citations.

### Study Selection

We developed a priori eligibility criteria for each KQ, which are described below. Two reviewers independently screened the titles and abstracts of the search results using broad criteria. We classified each study as “include,” “exclude,” or “unsure.” We retrieved the full text articles for all studies that were rated “include” or “unsure.” Two reviewers independently reviewed the full text of potentially relevant studies using a standard form that was pretested on a sample of studies. We resolved disagreements through consensus or third-party arbitration.

#### KQs 1 to 3 Decision Aids and Tools

We sought to identify research evaluating decisions aids or similar tools to guide decisionmaking with patients or their next-of-kin pertaining to insertion, continuation, or cessation of ECDs. ECDs included ICDs, CRT–ICDs, pacemakers, and VADs. Decisionmaking tools were defined according to the International Patient Decision Aid Standards Collaboration as: “…tools designed to help people participate in decisionmaking about health care options. They provide information on the options and help patients clarify and communicate the personal value they associate with different features of the options.”2

We initially searched for randomized controlled trials (RCTs), cluster RCTs, nonrandomized controlled trials (NRCT), pragmatic trials, and quasi-experimental pre-post test studies. Our population of interest was adult patients with or needing an ECD, regardless of age or condition. We did not prespecify outcomes.

Our initial searches did not identify any tools that had been evaluated in trials or other comparative studies. Therefore, we made a post hoc decision to search for studies of tools that had been evaluated using other methods based on the second set of searches (i.e., published and grey literature of nontrial designs).

#### KQ 4 Barriers to Decision Aids and Tools

For this question, we included studies with primary data that could be reasonably interpreted as pertaining to barriers (or conversely facilitators) to the use of decision tools or similar aids in relation to ECDs in eligible patients. We did not prespecify methodological criteria. As such, studies could use qualitative, survey, or other observational methods or include data that were reported as an adjunct to other methods, such as mixed methods studies.

### Methodological Quality

#### KQs 1 to 3 Decision Aids and Tools

To assess the methodological quality of RCTs and NRCTs, we planned to use the Cochrane Risk of Bias tool.3

To assess the quality of the decision tools, we used a previously validated systematic quality assessment framework for decision aids.4 This framework assesses quality in all stages of decision tools (that is, from development to content) and multiple facets of a tool, including the following domains: systematizing the development process; information about treatment options; presenting probabilities; clarifying and expressing values; using patient stories; guiding and coaching; disclosing conflicts of interest; providing internet access; balancing presentation of options; using plain language; basing information on up-to-date evidence; and establishing effectiveness. Two reviewers independently appraised the decision aids, and there were no discrepancies in their assessments.

#### KQ 4 Barriers to Decision Aids and Tools

We used different tools to assess the quality of studies depending on study design. For qualitative studies, we used the Critical Appraisal Skills Program tool for assessing qualitative research.5 For observational studies, we used either a tool for cohort studies6 or a tool for descriptive cross-sectional studies.7 We categorized studies as high, medium, or low quality.

One reviewer applied the tools, and a second reviewer independently checked the scores. We resolved differences in assessments by consensus.

### Data Extraction

#### KQs 1 to 3 Decision Aids and Tools

One reviewer extracted data from individual studies using standardized templates; a second reviewer independently verified the accuracy of data extraction. We used different templates for qualitative and quantitative studies.

#### KQ 4 Barriers to Decision Aids and Tools

We classified studies into three categories: qualitative studies describing general experiences with ECDs; quantitative studies addressing psychosocial outcomes; and mixed methods studies relating to communication.

For qualitative and mixed method studies, we extracted publication details (year, author, study title, journal, main focus of paper), methodological details (principle approach, data collection methods, sampling methods), and population characteristics (sex, age, recruitment criteria, country of study, device type). We noted if the participants were patients, health professionals, or caregivers. When possible, we recorded details regarding indication for ECD (primary or secondary prevention), New York Heart Association functional class, left ventricular ejection fraction, and disease (heart failure or non-heart failure). We also recorded the focus of the study in relation to ECD insertion, malfunction, deactivation, or end-of-life.

For quantitative studies focusing on psychosocial outcomes, we similarly extracted publication details, population characteristics, and the indication for ECD (primary or secondary prevention). We noted if the participants were patients, spouses, or other primary caregivers. We recorded which instruments were used to measure specific outcomes. For each outcome, we extracted baseline, followup, and change from baseline data, including information on the effect size and statistical significance, if available.

### Data Synthesis

#### KQs 1 to 3 Decision Aids and Tools

We present a narrative summary of the studies that provided data to address this question.

#### KQ 4 Barriers to Decision Aids and Tools

For qualitative studies on general experience with ECDs, we used the meta-ethnographic approach to synthesise findings.8,9 This approach provides a new synthesis of findings to account for the phenomenon being explored9 and involves a three-stage process including first-order findings, second-order interpretations, and higher-order abstractions. Through this process, studies are re-analyzed and compared in light of each other to produce new theory or knowledge.9,10

For quantitative studies with psychosocial outcomes, we used an integrative approach to synthesis. We chose this approach because, although the selected studies were the same topic, there were differences in methods and outcomes which precluded pooling of results.11 For the integrative review, we examined the findings of comparable studies in relation to each other, taking account of the methodological quality and differences in populations.11

For mixed methods studies on communication, we followed the same steps for quantitative studies of psychosocial outcomes.11

## Results

### Literature Search

We identified 1449 citations in our literature. After removal of duplicates, 1102 studies remained. Through the grey literature search, we identified 43 additional web citations containing potentially relevant content.

### Description of Included Studies (KQs 1 to 3)

We identified four studies that may have contained data relating to decision aids for insertion or deactivation. These included interventions for ECD populations using telephone counseling,12 discussions prior to13 or after14 insertion, and a disease-specific end-of-life planning intervention.15 Based on followup with authors via email, we determined that none of these interventions included a discussion of aspects of insertion, malfunction, or deactivation of ECDs.

Based on our search of the grey literature, we identified four patient decision aids for insertion of an ICD16 and pacemaker17 for patients at risk from arrhythmia and for an ICD18 and pacemaker19 for patients with heart failure (Table ES–1). These aids have not been evaluated using any formal research methodology (e.g., RCT) but have been independently validated as meeting quality criteria for decision aids.4 Given the lack of other studies evaluating decisions tools around deactivation, these four tools could be considered the “best available evidence.”

Table ES–1 Tools for ECDs Identified by Review^*^

Title of tool | Heart rate problems: Should I get an ICD? | Heart Rate Problems: Should I Get a Pacemaker? | Heart failure: Should I get an ICD? | Heart failure: Should I get a pacemaker (cardiac resynchronization therapy)?
Health Condition | Arrhythmia | Arrhythmia | Heart Failure | Heart Failure
Type | Treatment | Treatment | Treatment | Treatment
Options Included | Get an ICD. Don't get an ICD. | Get a pacemaker. Don't get a pacemaker. | Get an ICD. Don't get an ICD. | Get a pacemaker. Don't get a pacemaker.
Audience | People with heart rate problems but do NOT have heart failure considering whether to get an ICD. | People with heart rate problems but NOT heart failure considering getting a pacemaker. | People at risk of having an abnormal heart rhythm that could cause sudden death. | People with class III or class IV heart failure, symptoms not controlled with medication, an ejection fraction of 35% or less and tests showing the heart's ventricles are not beating at the right time.
Developer | Healthwise | Healthwise | Healthwise | Healthwise
Country of development | United States | United States | United States | United States
Year of last update or review | 2011 | 2010 | 2010 | 2010
Format | Web, paper | Web, paper | Web, paper | Web, paper
Language(s) | English | English | English | English

ICD = implantable cardiac defibrillator; OHRI = Ottawa Hospital Research Institute

* See Appendix C for copies of the tools and URLs for further information on the tools and their validation.

#### KQ 1 Are there validated decision aids and tools available for electronic cardiac devices?

We identified four decisions aids that addressed insertion of pacemakers and ICDs in patients with heart failure and arrhythmia (Table ES–1). We found no validated decision aids or tools that adequately address the deactivation of ECDs. The tools focusing on insertion included comprehensive content on technical aspects of insertion, but made limited references to implications for quality of life and generally lacked balance in terms of how the decision to insert was presented.

#### KQ 2 How effective are these decision aids and similar tools for promoting informed decisionmaking?

In contrast with current recommendations, these aids do not address deactivation in discussions about insertion. No aids were identified that addressed deactivation of ICDs, pacemakers, or VADs for any patient populations. Insertion was partially addressed by the tools, and quality was reduced by the lack of focus in discussion around insertion prior to deactivation. Indeed, deactivation was not addressed in any of the tools relating to insertion of either a pacemaker or ICD.

#### KQ 3 Is the Medicare population sufficiently represented in the published studies? If not, are the conclusions of the studies generalizable to the Medicare population?

Due to the lack of tools examining deactivation, the representation of the Medicare population is not currently an issue.

### Description of Included Studies (KQ 4)

#### Literature Search and Screening

The search for barriers to use of tools in the ECD populations identified a total of 97 potentially relevant studies of which 67 met the inclusion criteria. Included studies fell into the following three categories: a) 33 qualitative studies that contained data on patient experiences related to decisionmaking; b) 26 quantitative studies of psychosocial outcomes, all of which examined anxiety issues in patients with ECDs; and, c) 8 studies using mixed methods designs addressing communication issues. We present the results below according to these three categories.

#### Qualitative Studies of General Experiences

Qualitative research into patients' experiences consistently showed that patients often have poor knowledge of key aspects related to deactivation, including the role of the device and how their health would be affected by deactivation of the device. Communication with physicians was often poor, with professionals viewed as over-imposing their own values and priorities on patients. Patients reported wanting more discussions with a wider range of health professionals.

The most common threats to informed consent were patient passivity, lack of information on the implications of deactivation for daily living activities, and the psychosocial disruption caused by devices, notably the shocks from ICDs. Patient experiences appeared to change over time, with 3 months after insertion being notable for a higher need for more information and psychosocial support. Social support for patients around decisionmaking or psychosocial wellbeing was limited over time. Families and other caregivers were the main source of support provided, but were often seen to be overly protective.

Psychosocial disruptions were common across ECDs. However, research suggests that psychosocial disruptions were highest for ICDs due to the frequency and intensity of shocks.

Although current research presented limited sex- and age-based analyses, women appear to be prone to greater psychosocial sequelae from ICDs, and older adults may be more prone to lower social support.

#### Quantitative Studies of Psychosocial Outcomes

The quantitative studies of psychosocial outcomes corroborate the qualitative findings. The main factors influencing anxiety and depression were: shock frequency, Type D (distressed) personality, social and educational status, and age.

#### Studies of Communication

Communication-related factors that influenced psychosocial outcomes and quality of decisionmaking were: the presence or absence of organizational policies around deactivation; the lack of training and comfort among health professionals in initiative and maintaining dialogue with patients around deactivation; and poorly-timed discussions that were too near patients' end of life.

Patients reported that they would welcome more discussion with health professionals around deactivation and would be comfortable having these discussions in person or over the telephone with wider members of the multidisciplinary health care team.

## Discussion

Four decisions aids were identified that addressed insertion of pacemakers and ICDs in patients with heart failure and arrhythmia. No existing tools addressed the deactivation of ECDs. In contrast to guidelines, current tools do not address deactivation in discussions prior to insertion. Due to the lack of tools examining deactivation, generalizabililty to the Medicare population is not currently an issue.

Although current recommendations could be incorporated into high-quality decisions aids for each type of ECD, there are consistent indications that other barriers exist to high-quality decisionmaking and effective use of decision aids. These barriers include:

- Low patient knowledge of key aspects of deactivation, the role of the device,20,21 and how health could be affected by deactivation of the device.1,20,22,23,24,25
- Poor communication with physicians;26,27,28,29,30 professionals being seen to over-impose their own values and priorities on patients.27,31,24,29
- Widespread psychosocial disruptions32,33,34 across ECDs especially3 months after device insertion,21,35,24 and patients with: higher shock frequency,36,37,38,39 Type D personality,40,41,39,42 43 and adverse social and educational status,37,42 female sex,36,44,45,46 and older age.47,48
- Low patient social support for decisionmaking or psychosocial wellbeing and overly protective families and other caregivers.49,24,50,39
- Decisionmaking could be improved via: implementation of organizational policies around deactivation,26,51 better training of health professionals in instigating and maintaining dialogue with patients around deactivation,16,52,53,54,55 and instigating discussions earlier56,57 with a wider range of health professionals,27,22,23 markedly before the patients' end of life.58,56,59
- These discussions could be in person or over the telephone60 with wider members of the multidisciplinary health care team.27,22,23

This review identified that common barriers to attaining and maintaining informed consent are: gaps in basic knowledge about ECDs, disparities in values with health professionals, and patient anxiety. More positively, patients do appear to want to be involved more, know more, and receive support from different professional groups.

Deactivation of an ECD is an important aspect of health care that should be discussed openly and early in the care trajectory prior to insertion of the ECD. However, there is consistent evidence that physicians are not well trained to instigate and maintain this dialogue, that when it does occur the values and priorities of patients and professionals can be incongruent, and that patients often lack basic knowledge that will allow them to make choices about deactivation in an informed manner. Moreover, there was limited evidence that caregivers and family provide support that patients perceive as useful around deactivation decisions. Decisions about deactivation are likely to be complex due to the prevalence and negative effects of shocks on psychosocial wellbeing, particularly during the first year after insertion. Nevertheless, patients have voiced both a need and desire for more comprehensive information about the implications of deactivation and for support from other health professionals.

Health professionals have expressed different opinions over the legality and ethics of deactivation of ECDs. Clinicians have markedly different levels of comfort in addressing deactivation decisions, different views of their role and of the ethics and legality of these decisions. Generalizability is restricted as research has been based on relatively small, qualitative studies and surveys that have been mostly local and/or had relatively low response rates. Further, ECD deactivation emerged as a new and contentious issue only in recent years.

This review has identified research on patient perspectives regarding decisionmaking around ECDs. Though the overall quality of the qualitative, quantitative, and mixed methods studies included in the review was moderate, most research focused on aspects of insertion decisions. Even when deactivation was addressed, seldom was this done from the perspective of end-of-life care. Also, there was very little existing evidence on decisionmaking about ECDs by surrogate decisionmakers.

It is not necessarily surprising that there are no existing decision tools that adequately address deactivation either prior to insertion as part of the decision to insert the ECD or after insertion as a discrete decision. Clear guidance on the most contentious issues around deactivation relating to ICDs was only published in 2010.^20^ Many of the concerning patterns identified in this review around informed consent related to the deactivation of ICDs predate this guidance, and there was a lack of consensus prior to this around the ethics and legality of deactivation evident in both argument52-64 and practice.65

These guidelines may in time influence organizational policies and health care practice in relation to deactivation of ICDs and other ECDs, for which the same ethical and legal principles apply. High-quality decisionmaking that supports the principles and practices of informed consent and patient involvement in decisions is the best means to ensure care is legal and ethical.

Based on patient accounts of discussions about insertion and deactivation, the ability of practitioners to attain and maintain informed consent is likely to be constrained by basic gaps in knowledge and understanding. These gaps include aspects of device function, efficacy, and implications of deactivation, as well as basic knowledge of underlying health conditions. Though it may be surprising that such gaps exist even after years of treatment, similar gaps in basic knowledge are relatively common in people with advanced heart failure.66-68 Similarly, systematic reviews have demonstrated that untreated and unrecognized anxiety and depression are common in patients with coronary heart disease58 and heart failure.70 As such, many of the psychosocio-educational challenges in maintaining informed consent in people with ECDs occur in patients with other cardiac conditions and may be amenable to similar solutions.

### Future Research

Research is needed to develop discrete, high-quality decisions aids or similar tools to support deactivation of ECDs in eligible patient groups. Further, large-scale surveys are needed to establish the prevalence of organizational policies around deactivation in appropriate care providers and identify physician attitudes and practices to deactivation following publication of guidelines from the Heart Rhythm Society in 2010.

Trials and meta-analyses are needed to determine the effectiveness of multidisciplinary psychosocio-educational interventions to support patient knowledge, receptiveness, and psychosocial wellbeing. Early results of trials are promising, but telehealth and electronic interventions should be developed for rural populations.

Interventions are needed to support physicians and other health professionals to instigate and maintain dialogue with patients and maintain informed consent around insertion and deactivation. These interventions should offer assistance in how to provide noncoercive, balanced, and understandable support that is responsive to the needs and values of patients and/or surrogate decisionmakers.

Research should be focused on examining how surrogate decisionmakers make decisions about ECD deactivation and their perceived role and satisfaction with informed consent and support from health professionals.

### Applicability

The applicability of the trends identified in this review to the Medicare population is constrained by the relatively young mean age of participants in most studies and a lack of incorporation of age into analyses. Though a small number of studies do indicate that age may ameliorate some of the anxiety associated with shocks,71,72 the influence of age on patient experiences and outcomes has not been specifically examined in studies to date.

### Conclusions

We identified four decision aids that address insertion of pacemakers and ICDs in patients. However, these tools were of low quality and did not address deactivation prior to or, as a discrete decision, after insertion. In addition to the development of tools to inform and support decisions to insert or deactivate different types of ECDs, a number of common individual and contextual factors exist to reduce the quality of care and decision-making in ECD populations. Older age, female sex, and higher shock frequency in ICDs were all associated with higher psychosocial disruption that may further inhibit patients' ability to make decisions.

In addition to the development of separate tools that address deactivation of ECDs before and after insertion, healthcare can be improved via organizational policies that promote discussions markedly prior to the end of life, more widespread training of health professionals to discuss and counsel patients around insertion and deactivation decisions, and better utilization of multidisciplinary health care teams.

## References

1 Padeletti L, Arnar D, Boncinelli L, et al. EHRA Expert Consensus Statement on the management of cardiovascular implantable electronic devices in patients nearing end of life or requesting withdrawal of therapy. Europace. 2010;12(10):1480-89. [pmid: 20675674].
2 Elwyn G, O'Connor A, Stacey D, et al. Developing a quality criteria framework for patient decision aids: online international Delphi consensus process. BMJ. 2006;333:417. [pmid: 16908462].
3 Jadad AR, Moore RA, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
4 Elwyn G, O'Connor A, Stacey D, et al. Developing a quality criteria framework for patient decision aids: online international Delphi consensus process. BMJ. 2006;333(7565):417. [pmid: 16908462].
5 Critical Appraisal Skills Programme (CASP) and Evidence-based Practice: CASP qualitative appraisal tool. NHS Learning and Development. 2007. [cited 2011 July 4]. Available from: http://www.sph.nhs.uk/sph-files/casp-appraisal-tools/Qualitative%20Appraisal%20Tool.pdf.
6 NHS Learning and Development. Critical Appraisal Skills (CASP) and Evidence-based Practice: CASP cohort studies tool. 2004. [cited 2011 July 4]. Available from: http://www.sph.nhs.uk/sph-files/casp-appraisal-tools/cohort%2012%20questions.pdf.
7 11 questions to help you make sense of descriptive/cross-sectional studies. Albert Einstein College of Medicine of Yeshiva University NY. 2002. [cited 2011 July 4]. Available from: http://www.yu.edu/aecomdb/dfsm/Uploads/ugclerkshipinfo/cross-sectional%20study%20appraisal%20tool.pdf.
8 Noblit G, Hare R. Meta-ethnography: synthesizing qualitative data. London. Sage. 1988.
9 Pound P, Britten N, Morgan M, et al. Resisting medicines: a synthesis of qualitative studies of medication taking. Soc Sci Med. 2005;61:133-55. [pmid: 15847968].
10 Mays N, Pope C, Popay J. Systematically reviewing qualitative and quantitative evidence to inform management and policy making in the health field. J Health Serv Res Policy. 2005;10(Suppl 1):6-20. [pmid: 16053580].
11 Whittemore R, Knafl K. The integrative review: updated methodology. J Adv Nurs. 2005;52:546-53. [pmid: 16268861].
12 Dougherty CM, Lewis FM, Thompson EA, et al. Short-term efficacy of a telephone intervention by expert nurses after an implantable cardioverter defibrillator. Pacing Clin Electrophysiol. 2004;27(12):1594-602. [pmid: 15613121].
13 Lewin RJ, Coulton S, Frizelle DJ, et al. A brief cognitive behavioural preimplantation and rehabilitation programme for patients receiving an implantable cardioverter-defibrillator improves physical health and reduces psychological morbidity and unplanned readmissions. Heart. 2009;95:63-69. [pmid: 18070951].
14 Dunbar SB, Langberg JJ, Reilly CM, et al. Effect of a psychoeducational intervention on depression, anxiety, and health resource use in implantable cardioverter defibrillator patients. Pacing Clin Electrophysiol. 2009;32(10):1259-71. [pmid: 19796343].
15 Kirchhoff KT, Hammes BJ, Kehl KA, et al. Effect of a disease-specific planning intervention on surrogate understanding of patient goals for future medical treatment. J Am Geriatr Soc. 2010;58(7):1233-40. [pmid: 20649686].
16 Heart rate problems: should I get an implantable cardioverter-defibrillator (ICD)?. Healthwise Knowledgebase © 1995–2011. [cited 2011 July 4]. Available from: http://www.healthwise.net/fchp/Content/StdDocument.aspx?DOCHWID=abk4103.
17 Heart rate problems: should I get a pacemaker?. Healthwise Knowledgebase © 1995–2011. [cited 2011 July 4]. Available from: http://www.healthwise.net/fchp/Content/StdDocument.aspx?DOCHWID=abk4063.
18 Heart failure: should I get an implantable cardioverter-defibrillator (ICD)?. Healthwise Knowledgebase © 1995–2011. [cited 2011 July 4]. Available from: Available from: http://www.healthwise.net/fchp/Content/StdDocument.aspx?DOCHWID=uf9843.
19 Heart failure: should I get a pacemaker (cardiac resynchronization therapy)?. Healthwise Knowledgebase © 1995–2011. [cited 2011 July 4]. Available from: http://www.healthwise.net/fchp/Content/StdDocument.aspx?DOCHWID=uf9843.
20 Goldstein NE, Mehta D, Siddiqui S, et al. “That's like an act of suicide” patients' attitudes toward deactivation of implantable defibrillators. J Gen Intern Med. 2008;23(Suppl 1):7-12. [pmid: 18095037].
21 Flemme I, Bolse K, Ivarsson A, et al. Life situation of patients with an implantable cardioverter defibrillator: a descriptive longitudinal study. J Clin Nurs. 2001;10(4):563-72. [pmid: 11822504].
22 Bolse K, Hamilton G, Flanagan J, et al. Ways of experiencing the life situation among United States patients with an implantable cardioverter-defibrillator: a qualitative study. Prog Cardiovasc Nurs. 2005;20(1):4-10. [pmid: 15785164].
23 Eckert M, Jones T. How does an implantable cardioverter defibrillator (ICD) affect the lives of patients and their families?. Int J Nurs Pract. 2002;8(3):152-57. [pmid: 12000634].
24 Tagney J, James JE, Albarran JW. Exploring the patient's experiences of learning to live with an implantable cardioverter defibrillator (ICD) from one UK centre: a qualitative study. Eur J Cardiovasc Nurs. 2003;2(3):195-203. [pmid: 14622627].
25 Stewart GC, Weintraub JR, Pratibhu PP, et al. Patient expectations from implantable defibrillators to prevent death in heart failure. J Cardiac Fail. 2010;16(2):106-13. [pmid: 20142021].
26 Kelley AS, Reid MC, Miller DH, et al. Implantable cardioverter-defibrillator deactivation at the end of life: a physician survey. Am Heart J. 2009;157(4):702-8. [pmid: 19332199].
27 Dougherty CM, Benoliel JQ, Bellin C. Domains of nursing intervention after sudden cardiac arrest and automatic internal cardioverter defibrillator implantation. Heart Lung. 2000;29(2):79-86. [pmid: 10739483].
28 Berger JT, Gorski M, Cohen T. Advance health planning and treatment preferences among recipients of implantable cardioverter defibrillators: an exploratory study. J Clin Ethics. 2006;17(1):72-8. [pmid: 16689116].
29 Andersen J, Oyen N, Bjorvatn C, et al. Living with long QT syndrome: a qualitative study of coping with increased risk of sudden cardiac death. J Genet Couns. 2008;17(5):489-98. [pmid: 18719982].
30 Gibson D, Kuntz K, Levenson J, et al. Decision-making, emotional distress, and quality of life in patients affected by the recall of their implantable cardioverter defibrillator. Europace. 2008;10(5):540-4. [pmid: 18442964].
31 Steinke EE, Gill-Hopple K, Valdez D, et al. Sexual concerns and educational needs after an implantable cardioverter defibrillator. Heart Lung. 2005;34(5):299-308. [pmid: 16157184].
32 Sossong A. Living with an implantable cardioverter defibrillator: patient outcomes and the nurse's role. J Cardiovasc Nurs. 2007;22(2):99-104. [pmid: 17318034].
33 Prudente LA, Reigle J, Bourguignon C, et al. Psychological indices and phantom shocks in patients with ICD. J Interv Card Electrophysiol. 2006;15(3):185-90. [pmid: 17019638].
34 Ong L. Predicting psychological outcomes and antiarrhythmic therapies of defibrillator recipients: the role of dispositional vulnerability [dissertation]. Toronto. York University. 2008.
35 Sneed NV, Finch N. Experiences of patients and significant others with automatic implantable cardioverter defibrillators after discharge from the hospital. Prog Cardiovasc Nurs. 1992;7(3):20-24. [pmid: 1297142].
36 Bilge AK, Ozben B, Demircan S, et al. Depression and anxiety status of patients with implantable cardioverter defibrillator and precipitating factors. Pacing Clin Electrophysiol. 2006;29(6):619-26. [pmid: 16784428].
37 Van Den Broek KC, Nyklicek I, Denollet J. Anxiety predicts poor perceived health in patients with an implantable defibrillator. Psychosomatics. 2009;50(5):483-92. [pmid: 19855034].
38 Pauli P, Wiedemann G, Dengler W, et al. A priori expectancy bias and its relation to shock experience and anxiety: a naturalistic study in patients with an automatic implantable cardioverter defibrillator. J Behav Ther Exp Psychiatry. 2001;32(3):159-71. [pmid: 11934128].
39 Pedersen SS, Theuns DA, Jordaens L, et al. Course of anxiety and device-related concerns in implantable cardioverter defibrillator patients the first year post implantation. Europace. 2010;12(8):1119-26. [pmid: 20507853].
40 Van den Broek KC, Nyklicek I, Van der Voort PH, et al. Shocks, personality, and anxiety in patients with an implantable defibrillator. Pacing Clin Electrophysiol. 2008;31(7):850-57. [pmid: 18684282].
41 Pedersen SS, Spinder H, Erdman RAM, et al. Poor perceived social support in implantable cardioverter defibrillator (ICD) patients and their partners: cross-validation of the multidimensional scale of perceived social support. Psychosomatics. 2009;50(5):461-67. [pmid: 19855031].
42 Pedersen SS, Spindler H, Johansen JB, et al. Clustering of poor device acceptance and type D personality is associated with increased distress in Danish cardioverter-defibrillator patients. Pacing Clin Electrophysiol. 2009;32(1):29-36. [pmid: 19140910].
43 Denollet J. DS14: Standard assessment of negative affectivity, social inhibition, and Type D personality. Psychosom Med. 2005;67:89-97. [pmid: 15673629].
44 Fritzsche K, Forster F, Schweickhardt A, et al. Depressive coping is a predictor for emotional distress and poor quality of life in a German-Austrian sample of cardioverter-defibrillator implant recipients at 3 months and 1 year after implantation. Gen Hosp Psychiat. 2007;29(6):526-36. [pmid: 18022046].
45 Sowell LV, Sears SF, Walker RL, et al. Anxiety and marital adjustment in patients with implantable cardioverter defibrillator and their spouses. J Cardiopulm Rehabil Prev. 2007;27(1):46-49. [pmid: 17474644].
46 Fisher JD, Koulogiannis KP, Lewallen L, et al. The psychological impact of implantable cardioverter-defibrillator recalls and the durable positive effects of counseling. Pacing Clin Electrophysiol. 2009;32(8):1012-16. [pmid: 19659621].
47 Birnie DH, Sears SF, Green MS, et al. No long-term psychological morbidity living with an implantable cardioverter defibrillator under advisory: the Medtronic Marquis experience. Europace. 2009;11(1):26-30. [pmid: 19010798].
48 Van den Broek KC, Nyklicek I, Van der Voort PH, et al. Shocks, personality, and anxiety in patients with an implantable defibrillator. Pacing Clin Electrophysiol. 2008;31(7):850-57. [pmid: 18684282].
49 Wallace RL, Sears SF Jr., Lewis T, et al. Predictors of quality of life in long-term recipients of implantable cardioverter defibrillators. J Cardiopulm Rehab. 2002;22(4):278-81. [pmid: 12202849].
50 Fridlund B, Lindgren EC, Ivarsson A, et al. Patients with implantable cardioverter-defibrillators and their conceptions of the life situation: a qualitative analysis. J Clin Nurs. 2000;9(1):37-45. [pmid: 11022491].
51 Goldstein N, Carlson M, Livote E, et al. Management of implantable cardioverter-defribrillators in hospice: a nationwide survey. Ann Intern Med. 2010;152:296-99. [pmid: 20194235].
52 Lewis WR, Luebke DL, Johnson NJ, et al. Withdrawing implantable defibrillator shock therapy in terminally ill patients. Am J Med. 2006;119(10):892-6. [pmid: 17000222].
53 Goldstein NE, Mehta D, Teitelbaum E, et al. “It's like crossing a bridge” complexities preventing physicians from discussing deactivation of implantable defibrillators at the end of life. J Gen Intern Med. 2008;23(Suppl 1):2-6. [pmid: 18095036].
54 Cladwell PH, Arthur HM, Demers C. Preferences of patients with heart failure for prognosis communication. Can J Cardiol. 2007;23(10):791-96. [pmid: 17703257].
55 Sherazi S, Zareba W, Daubert JP, et al. Physicians' knowledge and attitudes regarding implantable cardioverter-defibrillators. Cardiol J. 2010;17(3):267-73. [pmid: 20535717].
56 Lampert R, Hayes DL, Annas GJ, et al. HRS expert consensus statement on the management of Cardiovascular Implantable Electronic Devices (CIEDs) in patients nearing end of life or requesting withdrawal of therapy. Heart Rhythm. 2010;7(7):1008-26. [pmid: 20471915].
57 Sulmasy DP. Within you/without you: biotechnology, ontology and ethics. J Gen Intern Med. 2007;23(Suppl 1):69-72. [pmid: 18095048].
58 General Medical Council. Treatment and care towards the end of life: good practice in decisionmaking. London. General Medical Council. 2010. [cited 2011 July 4]. Available from: http://www.gmc-uk.org/End_of_life.pdf_32486688.pdf.
59 Hunt SA, Abraham WT, Chin MH, et al. 2009 focused update incorporated into the ACC/AHA 2005 guidelines for the diagnosis and management of heart failure in adults: a report of the American College of Cardiology Foundation/American Heart Association task force on practice guidelines. Circulation. 2009;119:e391-e479. [pmid: 19324966].
60 Serber ER, Finch NJ, Leman RB, et al. Disparities in preferences for receiving support and education among patients with implantable cardioverter defibrillators. Pacing Clin Electrophysiol. 2009;32(3):383-90. [pmid: 19272070].
61 Lampert R, Hayes DL, Annas GJ, et al. HRS expert consensus statement on the management of Cardiovascular Implantable Electronic Devices (CIEDs) in patients nearing end of life or requesting withdrawal of therapy. Heart Rhythm. 2010;7(7):1008-26. [pmid: 20471915].
62 Braun TC, Hagen NA, Hatfield RE, et al. Cardiac pacemakers and implantable defibrillators in terminal care. J Pain Symtom Manag. 1999;18:126-31. [pmid: 10484960].
63 Berger JT. The ethics of deactivating implanted cardioverter defibrillators. Ann Intern Med. 2005;142:631-34. [pmid: 15838070].
64 Kapa S, Rotondi-Trevisan D, Mariano Z, et al. Psychopathology in patients with ICDs over time: results of a prospective study. Pacing Clin Electrophysiol. 2010;33(2):198-208. [pmid: 19930108].
65 Sherazi S, Daubert J, Block R, et al. Physicians' preferences and attitudes about end-of-life care in patients with an implantable cardioverter-defibrillator. Mayo Clin Proc. 2008;83:1139-41. [pmid: 18828973].
66 Clark AM, Freydberg N, McAlister FA, et al. Patient and informal caregivers' knowledge of heart failure: necessary but insufficient for effective self care. Eur J Heart Fail. 2009;11(6):617-21. [pmid: 19414477].
67 Horowitz CR, Rein SB, Leventhal H. A story of maladies, misconceptions and mishaps: Effective management of heart failure. Soc Sci Med. 2004;58(3):631-43. [pmid: 14652059].
68 Riegel B, Dickson VA. A situation-specific theory of heart failure self care. J Cardiovasc Nurs. 2008;23:190-96. [pmid: 18437059].
69 Linden W. Psychological treatments in cardiac rehabilitation: review of rationales and outcomes. J Psychosom Res. 2000;48:443-54. [pmid: 10880665].
70 Rutledge T, Reis V, Linke S, et al. Depression in heart failure: a meta-analytic review of prevalence, intervention effects, and associations with clinical outcomes. J Am Coll Cardiol. 2006;48:1527-37. [pmid: 17045884].
71 Van den Broek KC, Nyklicek I, Van der Voort PH, et al. Shocks, personality, and anxiety in patients with an implantable defibrillator. Pacing Clin Electrophysiol. 2008;31(7):850-57. [pmid: 18684282].
72 Birnie DH, Sears SF, Green MS, et al. No long-term psychological morbidity living with an implantable cardioverter defibrillator under advisory: the Medtronic Marquis experience. Europace. 2009;11(1):26-30. [pmid: 19010798].