# Peer Reviewers

We wish to acknowledge individuals listed below for their review of this report. This report has been reviewed in draft form by individuals chosen for their expertise and diverse perspectives. The purpose of the review was to provide candid, objective, and critical comments for consideration by the EPC in preparation of the final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.

- Nathan Goldstein
  Associate Professor
  Mount Sinai School of Medicine
  New York, NY
- Paul J. Hauptman
  Professor of Medicine
  Saint Louis University School of Medicine
  St. Louis, MO
- Rachel Lampert
  Associate Professor
  Yale School of Medicine
  New Haven, CT
- Lynne Warner Stevenson
  Professor
  Brigham and Women's Hospital
  Harvard Medical School
  Boston, MA