# Acknowledgments

The authors wish to thank the researchers who worked on the project (Megan Jerke, Zoe Hsu, Amanda Duncan, Dr. Alex Choby, and Melisa Spaling) and those who responded to queries regarding particular studies included in this review (Dr. Cynthia Dougherty, Dr. Sandra Dunbar, Dr. Nathan Goldstein, Dr. Karin Kirchhoff, Dr. Emily Kuhl, Dr. Robert JP Lewin, and Dr. Samual Sears). We are also very thankful to the consultants for the project (Dr. James Beattie, Dr. Tiny Jaarsma, Dr. Patricia Davidson, and Dr. Patricia Strachan). We thank Jennifer Seida for copy-editing.