# Methodological Quality of Included Studies

Qualitative Studies

Author(s) | Study Quality (L/M/H) | Assessment Tool Used | Main Strengths | Main Weaknesses
Agard et al., 2007^101^ | M | JBI–QARI | Sampling rationale; congruent study design | Sample interview questions not provided
Anderson, 2004^85^ | L | JBI–QARI | Data management; ethical protection of participants | Interpretation of data is questionable; conclusions seem not to flow from data
Andersen et al., 2008^102^ | M | JBI–QARI | Detailed, rigorous procedures enhance trustworthiness | Low enrollment rate
Beery, 1998^103^ | H | JBI–QARI | Rigorous data collection and analysis methods | Leading interview questions
Beery et al., 2002^105^ | H | JBI–QARI | Rigorous data collection and analysis methods | Potential sampling bias
Berger et al., 2006^89^ | L | Cross-sectional Appraisal Tool^*^ | High enrollment rate | Instrument validity/reliability measures not reported; data analysis procedures not described
Bolse et al., 2002^90^ | M | Cohort–CASP | Detailed sampling and instrument descriptions | Different end-points among the sample populations
Bolse et al., 2005^86^ | L | JBI–QARI | Data analysis well described | Potential sampling bias; methodology (phenomenography) is not convincing
Burke, 1995^87^ | H | JBI–QARI | Methodologically rigorous; procedures described enhance trustworthiness | Quotes are not tied to interview participants
Dickerson, 2002^104^ | H | JBI–QARI | Large sample size; appropriate methods for phenomenology | Quotes are not tied to interview participants
Dougherty, 1994^91^ | M | Cohort–CASP | Multiple methods and recruitment sites | Interview data not represented in findings; potential sampling bias
Dougherty, 2000^88^ | M | JBI–QARI | Thorough methods; discusses data saturation | Interview focus does not reflect research purpose
Dunbar et al., 1993^106^ | M | JBI–QARI | Validity and reliability reported | No information on data analysis
Eckert, 2002^95^ | L | JBI–QARI | Findings deepen nursing practice | Numerous data collection strategies not reported; interpretation of data is questionable
Flemme, 2001^92^ | H | Cohort–CASP | Thoroughly describes theoretical framework; discusses reasons for nonparticipation | No rationale for selection of specific time points
Fridlund et al., 2000^107^ | L | JBI–QARI | Diverse sample population | Analysis appears superficial
Gibson et al., 2008^110^ | M | Cohort–CASP | Large sample size; detailed description of statistical analysis | Validity/reliability measures not reported for one instrument
Goldstein et al., 2008^45^ | M | JBI–QARI | Sound methods and rationale for data collection | Relatively homogenous sample
Kaufman, 2011^1^ | H | JBI–QARI | Case studies discussed in wider ethnographic context | None identified
Kelley, 2009^58^ | M | Cross–sectional Appraisal Tool | Survey was pilot tested | Greater variation in vignettes
Lewis, 2006^12^ | M | Cohort–CASP | Detailed patient demographics table | Retrospective data collection; no description of data analysis
Matlock, 2010^96^ | M | JBI–QARI | Detailed description of team approach to analysis | Interview questions not consistent among participants
Noyes, 2009^108^ | M | RCT–CASP | Long followup period; account for missing data | Not clear how randomization was conducted
Ong, 2008^111^ | M | Cohort–CASP | Double-blind, randomly assigned intervention | Low participation rate
Prudente et al., 2006^109^ | L | Case control–CASP | Discusses recruitment and blinding | No baseline data established; convenience sampling from single recruitment site
Sneed et al., 1992^97^ | M | JBI–QARI | Sound data collection and analysis strategies | Criteria for inclusion not reported
Sossong et al., 2007^93^ | H | Cross-sectional Appraisal Tool | Pilot study; external validation of instrument | Relatively homogenous sample
Steinke et al., 2005^98^ | H | JBI–QARI | Sound data collection and analysis strategies | Quotations are not tied to interview participants
Stewart, 2010^112^ | M | Cohort–CASP | Appropriate analysis methods | Survey tool not validated; did not report size of confidence intervals
Strachan et al., 2011^47^ | H | JBI–QARI | Strong grounded theory approach and methods | Size of eligible sample not reported
Tagney, 2003^99^ | M | JBI–QARI | Interview guide was piloted | Low participation rate
Wallace et al., 2002^94^ | H | Cross–sectional Appraisal Tool | Detailed description of measures | Sample is largely male
Williams et al., 2004^100^ | L | JBI–QARI | Corroboration of data findings with participants | Ethical approval not reported; analysis appears superficial

CASP = Critical Appraisal Skills Programme, Oxford; H = high; JBI–QARI=Joanna Briggs Institute–Qualitative Assessment and Review Instrument; L = low; M = medium; RCT = randomized controlled trial

* Albert Einstein College of Medicine

Quantitative Studies

Author(s) | Study Quality (L/M/H) | Assessment Tool Used | Main Strengths | Main Weaknesses
Bilge et al., 2006^114^ | M | CASP | Questionnaires were validated; long-term followup | No reporting on confidence intervals or effect sizes; small number of female participants
Thomas et al., 2009^119^ | H | CASP | Long-term followup; in-depth description of statistical analysis | 47% response rate; 42% of attrition rate
Van den Broek et al., 2008^120^ | H | CASP | 84% response rate; large sample size; in-depth description of statistical analysis | Small number of female participants
Van Den Broek et al., 2009^121^ | H | CASP | Large sample size; in-depth description of analysis process; confounding variables were controlled | Small number of female participants
Pauli et al., 2001^122^ | M | CASP | In-depth description of statistical analysis; results were consistent with previous studies using the same experimental procedures | Small sample size; not all confounding variables were controlled
Undavia et al., 2008^124^ | M | CASP | 90% response rate | No reporting on confidence intervals or effect sizes; validity/reliability measures not reported for one instrument
Van Den Broek et al., 2006^132^ | L | Cross–Sectional Appraisal Tool^*^ | 90% response rate | Small sample size; results were mostly descriptive findings
Fisher et al., 2009^139^ | M | CASP | No dropout; in-depth description of study design and statistical analysis | 27% of response rate; number of female patients was small to determine sex differences
Birnie et al., 2009^115^ | H | CASP | In-depth description of statistical analysis; sample size was determined by power calculation; long-term followup | Small number of female participants
Carroll et al., 2010^116^ | H | CASP | Equal number of male and female participants in the cohorts; validity/reliability of measures were reported; in-depth description of statistical analysis | Small sample size; no reporting on confidence intervals or effect sizes
Crossmann et al., 2007^127^ | M | CASP | Sample size was determined by power calculation; effect sizes were reported | 43.5% of attrition rate
Wheeler et al., 2009^133^ | M | CASP | Long-term followup | Small sample size; not all confounding variables were controlled
Dougherty et al., 2009^129^ | H | CASP | 86% of response rate; 9.1% attrition rate; in-depth description of statistical analysis | Small number of male participants
Crow et al., 1998^128^ | L | CASP | Long-term followup; assessment tool used is well validated | No description of statistical analysis; only reported descriptive findings
Pedersen et al., 2009^125^ | M | CASP | Validity/reliability of measures were reported; in-depth description of statistical analysis; confounding variables were controlled | Only included partners of ICD patients and not CHF patients; larger sample size in the ICD cohort
Pedersen et al., 2009^134^ | H | Cross–sectional Appraisal Tool | Large sample size; 86% of response rate; in-depth description of statistical analysis; odds ratios with 95% confidence intervals were reported for significant findings | Small number of female participants
Pedersen et al., 2010^131^ | H | CASP | In-depth description of statistical analysis; confounding variables were accounted; odds ratios with 95% confidence intervals were reported for significant findings | Small number of female participants
Pedersen et al., 2005^135^ | H | Cross–sectional Appraisal Tool | 82% of response rate; large sample size; confounding variables were accounted; odds ratios with 95% confidence intervals were reported for significant findings | Small number of female participants
Sowell et al., 2007^136^ | M | Cross–sectional Appraisal Tool | Effect size was reported | Small number of female participants
Spindler et al., 2009^137^ | H | Cross–sectional Appraisal Tool | 86% of response rate; in-depth description of statistical analysis | Small number of female participants
Craney et al., 1997^138^ | H | Cross–sectional Appraisal Tool | Sample size was determined by power calculation; in-depth description of statistical analysis and data transformation | Small number of female participants
Fritzsche et al., 2007^130^ | M | CASP | Missing data were replaced using statistical techniques | 37% of attrition rate; small number of female participants; confounding variables were not controlled in analysis
Petrucci et al., 1999^123^ | L | CASP | Long-term followup | Small sample size; no statistical analysis; only reported descriptive findings
Chamberlain, 2008^126^ | L | CASP | No missing data | Small sample size; no description of statistical analysis
Duru et al., 2001^117^ | M | CASP | Large sample size | Validity/reliability measures not reported for one instrument ; not all confounding variables were controlled
Serber et al., 2003^118^ | M | CASP | Confounding variables were accounted | Number of female participants was small to determine gender differences

CASP = Critical Appraisal Skills Programme, Oxford; CHF = congestive heart failure; H = high; ICD = implantable cardioverter-defibrillator; L = low; M=medium,

* Albert Einstein College of Medicine

Mixed Method Studies

Author(s) | Study Quality (L/M/H) | Assessment Tool Used | Main Strengths | Main Weaknesses
Goldstein et al., 2008^46^ | H | JBI–QARI | Rigorous data collection and analysis methods | Not identified
Goldstein et al., 2004^42^ | M | JBI–QARI | 74% response rate; large sample size | Sample interview questions not provided
Goldstein et al., 2010^61^ | M | Cross–sectional Appraisal Tool^*^ | Reported results of sensitivity analysis | 50% response rate; instrument validity/reliability measures not reported
Cladwell et al., 2007^147^ | H | JBI–QARI | 71% response rate; rigorous data collection and analysis methods | Sample is largely male
Serber et al., 2009^148^ | M | Cross–sectional Appraisal Tool | Large sample size; detailed description of statistical analysis | Relatively homogenous sample; instrument validity/reliability measures not reported
Stutts et al., 2007^149^ | M | Cross–sectional Appraisal Tool | 84% response rate; detailed description of statistical analysis | Relatively homogenous sample
Sherazi et al., 2008^16^ | L | Cross–sectional Appraisal Tool | Detailed participant demographics table | 43% response rate; instrument validity/reliability measures not reported
Sherazi et al., 2010^150^ | M | Cross–sectional Appraisal Tool | Detailed description of statistical analysis | 33% response rate; instrument validity/reliability measures not reported

H = high; JBI–QARI = Joanna Briggs Institute–Qualitative Assessment and Review Instrument; L = low; M = medium

* Albert Einstein College of Medicine