# Evidence Tables (KQ 4)

Qualitative Studies Included on General Experiences

Author(s) | Approach | Population | Device type | Foci | Sample (M/F) | Sample Description | Study Quality (H/M/L)
Agard et al., 2007^101^ | General | HF | ICD only | Insertion | 25M, 6F | Pt perspectives on their role in initiating ICD therapy | M
Anderson, 2004^85^ | Grounded theory | Non–HF | Pacemaker | Living with technology | 8M | War veterans with pacemakers | L
Andersen et al., 2008^102^ | Systematic text condensation (Giorgi) | Non–HF | ICD only | Daily life challenges | 3M, 4F (not all had ICD) | Pts with a congenital disease | M
Beery, 1998^103^ | Phenomenology | Non–HF | Pacemaker | Living with biotechnology | 11F | Female pts perspectives | H
Beery et al., 2002^105^ | Life story method (Hall) | Non–HF | Pacemaker | Adjustment | 11F | Female pts perspectives | H
Berger et al., 2006^89^ | Survey | HF Non–HF | ICD only | Deactivation | 47M, 10F | Pts with ICD for >1 month | L
Bolse et al., 2002^90^ | Longitudinal survey | HF Non–HF | ICD only | Life situation | 42M, 14F | Pre- and post-ICD implant | M
Bolse et al., 2005^86^ | Grounded theory (weak phenomenography) | HF | ICD only | Living with an ICD | 8M, 6F | Pt perceptions of their life situation | L
Burke, 1995^87^ | Grounded theory | HF Non–HF | ICD only | Insertion | 14M, 10F | Pt perspectives on living with ICD | H
Dickerson, 2002^104^ | Phenomenology | Non–HF | ICD only | Living with an ICD | 18M, 41F | Pt perspectives on living with ICD | H
Dougherty, 1994^91^ | Longitudinal survey | HF | ICD only | Insertion; adjustment | 13M, 2F | Pt and family perspectives on living with an ICD | M
Dougherty et al., 2000^88^ | Grounded theory | Non–HF | ICD only | Insertion (1^st^ year following) | 13M, 2F | Pt and family experiences of ICD | M
Dunbar et al., 1993^106^ | Mixed methods | Non–HF | ICD only | Shock discharge | 20M, 2F | Pt experiences of ICD shocks | M
Eckert et al., 2002^95^ | General (weak phenomenology) | HF | ICD only | Daily life challenges | 3M Cgs | Pt and family ICD experience | L
Flemme et al., 2001^92^ | Longitudinal survey | HF | ICD only | Life situation | 42M, 14F | Life changes of ICD Pts over 1 year period | H
Fridlund et al., 2000^107^ | Phenomenography | HF | ICD only | Life conceptions | 10M, 5F | Pt life conceptions | L
Gibson et al., 2008^110^ | Cohort | Not reported | ICD only | Malfunction | 22M, 9F | Effect of device recall on Pts | M
Goldstein et al., 2008^45^ | Grounded theory | HF | ICD only | Deactivation/End-of-life | 10M, 5F | Pt attitudes towards deactivation | M
Kaufman et al., 2011^1^ | Ethnography | HF | ICD only | Insertion, End-of-life | 2 M | ICD–related ethical dilemmas for pts≥80 years | H
Kelley et al., 2009^58^ | Survey | Non–HF | ICD only | Deactivation | 374M, 184F HP | Physician attitudes re: ICD deactivation | M
Lewis et al., 2006^12^ | Cohort | HF Non–HF | ICD only | Deactivation | 51M, 12F | ICD withdrawal as comfort care for terminally ill | M
Matlock et al., 2010^96^ | General | HF | ICD, LVAD, pacemaker | Insertion | 16M, 6F | Pt styles of decisionmaking in relation to HF | M
Noyes et al., 2009^108^ | Randomized trial | HF | ICD only | Quality of life | 499M, 102F | Pt perspectives on ICD and quality of life | M
Ong, 2008^111^ | Cohort | HF Non–HF | ICD only | Daily life challenges | 105M, 25F | Effects of CBT intervention | M
Prudente et al., 2006^109^ | Case control | Not reported | ICD only | Quality of life | 59M, 16F | Phantom shocks in ICD pts | L
Sneed et al., 1992^97^ | General | HF | ICD only | Life adjustments | 10M, 5F (14 Cgs) | ICD recipients and significant others | M
Sossong, 2007^93^ | Survey | HF | ICD only | Living with an ICD | 79M, 11F | HF pts living with ICD | H
Steinke et al., 2005^98^ | General | Not reported | ICD only | General | 10 M, 2F (4Cgs) | ICD pts and intimacy with partners | H
Stewart et al., 2010^112^ | Cohort | HF | ICD only | Deactivation | 70M, 35F | Pt expectations of ICDs | M
Strachan et al., 2011^47^ | Grounded theory | HF Non–HF | ICD only | End-of-life | 24M, 6F | Pt perspectives on end-of-life care | H
Tagney et al., 2003^99^ | General | HF | ICD only | Living with an ICD | 6M, 2F | Pt experiences of learning to live with ICD | M
Wallace et al., 2002^94^ | Survey | HF Non–HF | ICD only | Psychosocial sequelae | 44M, 14F | ICD for treatment of arrhythmias | H
Williams et al., 2004^100^ | General | HF | ICD only | Living with an ICD | 8M, 3F (9F, 2M Cgs) | Pt and Cgs support group involvement | L

CBT = cognitive behavioral therapy; Cgs = caregivers; F = female; H = high; HF = heart failure; HP = health professionals; ICD = implantable cardioverter-defibrillator; L = low; LVAD = left ventricular assist device; M = male; M = medium; pt = patient

Quantitative Studies Included on Psychosocial Outcomes

Author(s) | Study Design | Country | Sample (M/F) Pts / age(years) | Device | Foci | Study Quality (H/M/L)
Bilge et al., 2006^114^ | Cohort | Turkey | 91 Pts 79M, 12F Mean age: 53 yrs Range: 18–86 yrs | ICD | Shock vs. no shock | M
Thomas et al., 2009^119^ | Cohort | U.S., Canada, New Zealand | 57 Pts 47M, 10F Mean age: 59.8 yrs Range: 51–69.3 yrs | ICD | Shock vs. no shock | H
Van den Broek et al., 2008^120^ | Cohort | The Netherlands | 308 Pts 254M, 54F Mean age: 62.6 yrs Range: 24–79 yrs | ICD | Shock vs. no shock | H
Van Den Broek et al., 2009^121^ | Cohort | The Netherlands | 205 Pts 179M, 26F Mean age: 62.1 yrs Range: 24–79 yrs | ICD | Shock vs. no shock | H
Pauli et al., 2001^122^ | Cohort | Germany | 24 Pts Mean age: 53 yrs Range: 35–60 yrs | ICD | Shock vs. no shock | M
Undavia et al., 2008^124^ | Cohort | U.S. | ICD recall group: 61 Pts 43M, 18F Mean age: 67.3 yrs Control group: 43 Pts 28M 15F Mean age: 64.6 yrs | ICD | Device recall vs. control | M
Van Den Broek et al., 2006^132^ | Repeated measures | The Netherlands | 33 Pts 27M, 6F Mean age: 60 yrs | ICD | Device recall vs. control | L
Fisher et al., 2009^139^ | Trial | U.S. | 100 Pts 78M 22F | ICD | Device recall vs. control | M
Birnie et al., 2009^115^ | Cohort | Canada | Device recall: 86 Pts Mean age: 67.7 yrs Control: 94 Pts Mean age: 64.9 yrs | ICD | Device recall vs. control | H
Carroll et al., 2010^116^ | Cohort | Canada | Primary prevention: 15 Pts Secondary prevention: 15 Pts | ICD | Primary vs. secondary prevention | H
Crossmann et al., 2007^127^ | Repeated measures | Germany | 35 Pts 30M, 5F Mean age: 57 yrs Range: 35–65 yrs | ICD | Psychosocial sequelae | M
Wheeler et al., 2009^133^ | Repeated measures | NR | 33 Pts 26M, 7F Mean age: 63.4 yrs | ICD | Psychosocial sequelae | M
Dougherty et al., 2009^129^ | Repeated measures | U.S. | 100 partners of ICD Pts 36M, 164F Mean age: 60.9 yrs | ICD | Psychosocial sequelae | H
Crow et al., 1998^128^ | Repeated measures | U.S. | 35 Pts | ICD | Psychosocial sequelae | L
Pedersen et al., 2009^125^ | Cohort | The Netherlands | 446 Pts 261M, 185F Mean age: 61.6 yrs | ICD | Psychosocial sequelae | M
Pedersen et al., 2009^134^ | Cross-sectional | Denmark | 557 Pts 456M, 101F Mean age: 61.9 yrs | ICD | Psychosocial sequelae | H
Pedersen et al., 2010^131^ | Repeated measures | The Netherlands | 348 Pts 275M, 73F | ICD | Psychosocial sequelae | H
Pedersen et al., 2005^135^ | Cross-sectional | The Netherlands | 182 Pts 147M, 35F Mean age: 62 yrs Range: 16–84 yrs | ICD | Psychosocial sequelae | H
Sowell et al., 2007^136^ | Cross-sectional | U.S. | 62 Pts 31M, 9F Mean age: 66 yrs | ICD | Psychosocial sequelae | M
Spindler et al., 2009^137^ | Cross-sectional | Denmark | 535 Pts 438M, 97F Mean age: 61.5 yrs | ICD | Psychosocial sequelae | H
Craney et al., 1997^138^ | Cross-sectional | U.S. | 75 Pts Mean age: 64.5 yrs Range: 21–84 yrs | ICD | Coping strategies | H
Fritzsche et al., 2007^130^ | Repeated measures | Germany | 180 Pts 145M, 35F | ICD | Coping strategies | M
Petrucci et al., 1999^123^ | Cohort | U.S. | 21 LVAD Pts 18M, 3F Mean age: 49.6 yrs Range:16–66 yrs 13 VAD Pts 6M, 7F Mean age: 56.5 yrs Range: 46–73 yrs | LVAD and VAD | Psychosocial sequelae | L
Chamberlain (2008)126 | Cohort | U.S. | 36 Pts 36 M Range: 46–90 yrs | ICD and pacemaker | Psychosocial sequelae | L
Duru et al., 2001^117^ | Cohort | Switzerland | 152 Pts 114M, 38F Mean age: 58 yrs Range: 40–70 yrs | ICD and pacemaker | Psychosocial sequelae | M
Serber et al., 2003^118^ | Cohort | U.S. | 96 Pts 66M, 26F Mean age: 62.2 yrs | ICD | Sleep quality | M

F = female; H = high; ICD = implantable cardioverter-defibrillator; L = low; LVAD = left ventricular assist device; M = male; M = medium; NR = not reported; pts = patients; VAD = ventricular assist device; yrs = years

Studies Included on Communication

Author(s) | Study Design | Country | Sample (M/F) Pts / age(years) | Device | Foci | Study Quality (H/M/L)
Goldstein et al., 2008 46 | Qualitative | U.S. | 12 physicians Mean age: 36.5 yrs Range: 33–61 yrs | ICD | Deactivation | H
Goldstein et al., 2004 42 | Mixed method | U.S. | 100 next-of-kin of ICD pts | ICD | Deactivation | M
Goldstein et al., 2010^61^ | Cross-sectional | U.S. | 414 hospices | ICD | Deactivation | M
Cladwell et al., 2007^147^ | Qualitative | Canada | 20 Pts 14M, 6F | ICD | Communication | H
Serber et al., 2009^148^ | Cross-sectional | U.S. | 108 participants 81M, 26F | ICD | Communication | M
Stutts et al., 2007^149^ | Cross-sectional | U.S. | 66 Pts Mean age: 61 yrs Range: 33–93 yrs | ICD | Communication | M
Sherazi et al., 2008^16^ | Cross-sectional | U.S. | 87 surveys | ICD | Training | L
Sherazi et al., 2010^150^ | Cross-sectional | U.S. | 110 surveys | ICD | Training | M

H = high; ICD = implantable cardioverter-defibrillator; L = low; M = medium; Pts = patients