# List of Excluded Studies

## Intervention Studies

1 Dougherty CM, Lewis FM, Thompson EA, et al. Short-term efficacy of a telephone intervention by expert nurses after an implantable cardioverter defibrillator. Pacing Clin Electrophysiol. 2004;27(12):1594-602. (No relevant data). [pmid: 15613121].
2 Dunbar SB, Langberg JJ, Reilly CM, et al. Effect of a psychoeducational intervention on depression, anxiety, and health resource use in implantable cardioverter defibrillator patients. Pacing Clin Electrophysiol. 2009;32(10):1259-71. (No relevant data). [pmid: 19796343].
3 Lewin RJ, Coulton S, Frizelle DJ, et al. A brief cognitive behavioural preimplantation and rehabilitation programme for patients receiving an implantable cardioverter-defibrillator improves physical health and reduces psychological morbidity and unplanned readmissions. Heart. 2009;95:63-69. (No relevant data). [pmid: 18070951].
4 Kirchhoff KT, Hammes BJ, Kehl KA, et al. Effect of a disease-specific planning intervention on surrogate understanding of patient goals for future medical treatment. J Am Geriatr Soc. 2010;58(7):1233-40. (No relevant data). [pmid: 20649686].

## Qualitative Studies

1 Bostwick JM, Sola CL. An updated review of implantable cardioverter/defibrillators, induced anxiety, and quality of life. Psychiatr Clin North Am. 2007;30(4):677-88. (Review). [pmid: 17938040].
2 Edelman S, Lemon J, Kirkness A. Educational intervention for patients with automatic implantable cardioverter defibrillators. Aust J Adv Nurs. 2007;24(3):26-32. (No relevant data). [pmid: 17518162].
3 Hall P, Sanford JT, Demi AS. Patterns of decision making by wives of patients with life-threatening cardiac disease. J Fam Nurs. 2008;14(3):347-62. (No relevant data). [pmid: 18780888].
4 Kobza R, Erne P. End-of-life decisions in ICD patients with malignant tumors. Pacing Clin Electrophysiol. 2007;30(7):845-9. (No relevant data). [pmid: 17584265].
5 Marinskis G, van Erven L, EHRA Scientific Initiatives Committee. Deactivation of implanted cardioverter-defibrillators at the end of life: Results of the EHRA Survey. Europace. 2010;12:1176-77. (No relevant data). [pmid: 20663788].
6 Mueller PS, Hook CC, Hayes D. Ethical analysis of withdrawal of pacemaker or implantable cardioverter-defibrillator support at the end of life. Mayo Clin Proc. 2003;7:959-63. (No relevant data). [pmid: 12911044].
7 Mueller PS, Swetz KM, Freeman MR, et al. Ethical analysis of withdrawing ventricular assist device support. Mayo Clin Proc. 2010;85(9):791-7. (No relevant data). [pmid: 20584919].
8 Pedersen SS, Van Den Broek KC, Sears SF Jr. Psychological intervention following implantation of an implantable defibrillator: A review and future recommendations. Pacing Clin Electrophysiol. 2007;30(12):1546-54. (Review). [pmid: 18070312].
9 Rahmoeller G, Moss AJ. Comments on ethical issues with implantable defibrillators by F. James Brennan. Pacing Clin Electrophysiol. 2004;27(7):899-900. (No relevant data). [pmid: 15271006].
10 Rizzieri AG, Verheijde JL, Rady MY, et al. Ethical challenges with the left ventricular assist devices as a destination therapy. Philos Ethics Humanit Med. 2008;3(20). [doi: 10.1186/747-5341-3-20]. (No relevant data). [pmid: 18694496].
11 Schoenfeld MH. Contemporary pacemaker and defibrillator device therapy: Challenges confronting the general cardiologist. Circulation. 2007;115(5):638-53. (No relevant data). [pmid: 17283279].
12 Simpson CS, Gillis AM. The pacemaker and implantable cardioverter defibrillator recall issue - A Canadian perspective. Can J Cardiol. 2006;22(6):467-71. (No relevant data). [pmid: 16685309].
13 Strachan PH, Ross H, Rocker GM, et al. Canadian Researchers at the End of Life Network (CARENET). Mind the gap: Opportunities for improving end-of-life care for patients with advanced heart failure. Can J Cardiol. 2009;25(11):635-40. (No relevant data). [pmid: 19898695].
14 Tagney J. A literature review comparing the experiences and emergent needs of adult patients with permanent pacemakers (PPMs) and implantable cardioverter defibrillators (ICDs). J Clin Nurs. 2010;19:2081-89. (No relevant data). [pmid: 20477907].
15 Vazquez LD, Conti JB, Sears SF. Female-specific education, management, and lifestyle enhancement for implantable cardioverter defibrillator patients: The FEMALE-ICD study. Pacing Clin Electrophysiol. 2010;33(9):1131-40. (No relevant data). [pmid: 20487354].
16 V itale MB, Funk M. Quality of life in younger persons with an implantable cardioverter defibrillator. Dimens Crit Care Nurs. 1995;14(2):100-11. (No relevant data). [pmid: 7889798].

## Communication Studies

1 Cosgriff JA, Pisani M, Bradley EH, et al. The association between treatment preferences and trajectories of care at the end-of-life. J Gen Intern Med. 2007;22(11):1566-71. (No relevant data). [pmid: 17874168].
2 Duru F. Telephone calls from nurses can improve symptoms, anxiety, and knowledge among ICD recipients. Evid Based Cardiovasc Med. 2005;9(2):136-37. (No relevant data). [pmid: 16380012].
3 Field ME, Sweeney MO. Socio-economic analysis of cardiac resynchronization therapy. J Interv Card Electrophysiol. 2006;17(3):225-36. (No relevant data). [pmid: 17372813].
4 Geist M, Newman D, Greene M, et al. Permanent explantation of implantable cardioverter defibrillators. Pacing Clin Electrophysiol. 2000;23(12):2024-9. (No relevant data). [pmid: 11202242].
5 Goldstein N, Bradley E, Zeidman J, et al. Barriers to conversations about deactivation of implantable defibrillators in seriously ill patients. J Am Coll Cardiol. 2009;54(4):371-4. (No relevant data). [pmid: 19608038].
6 Powell-Cope GM, Luther S, Neugaard B, et al. Provider-perceived barriers and facilitators for ischaemic heart disease (IHD) guideline adherence. J Eval Clin Pract. 2004;10(2):227-39. (No relevant data). [pmid: 15189389].
7 Rodriguez KL, Appelt CJ, Switzer GE, et al. Veterans' decision-making preferences and perceived involvement in care for chronic heart failure. Heart Lung. 2008;37(6):440-8. (No relevant data). [pmid: 18992627].
8 Sears SF, Todaro JF, Lewis TS, et al. Examining the psychosocial impact of implantable cardioverter defibrillators: A literature review. Clin Cardiol. 1999;22(7):481-89. (Review). [pmid: 10410293].

## Psychosocial Studies

1 Burke JL, Hallas CN, Clark-Carter D, et al. The psychosocial impact of the implantable cardioverter defibrillator: A meta-analytic review. Br J Health Psychol. 2003;8(Pt 2):165-78. (Review). [pmid: 12804331].
2 Wόjcicka M, Lewandowski M, Smolis-Bak E, et al. Psychological and clinical problems in young adults with implantable cardioverter-defibrillators. Kardiol Pol. 2008;66(10):1050-60. (Not English). [pmid: 19006026].
3 Zayac S, Finch N. Recipients' of implanted cardioverter-defibrillators actual and perceived adaptation: A review of the literature. J Am Acad Nurse Pract. 2009;21:549-56. (Review). [pmid: 19796289].