# Search Strategies

Table A–1 MEDLINE–OVID Version

Limits: trials, observational/qualitative studies; English only, 1990 – present Date searched: 6Dec10 Results: 395 trials; 3952 observational/qualitative studies
1. heart failure/th; 2. heart diseases/th; 3. Arrhythmias, cardiac/th; 4. Myocardial ischemia/th; 5. Ventricular dysfunction, left/th; 6. or/1-5; 7. exp Pacemaker, Artificial/; 8. ((artificial or cardiac) adj2 pacemaker*).mp.; 9. pacemaker*.tw.; 10. (PPM and pacemaker*).tw.; 11. exp Heart-Assist Devices/; 12. heart conduction system/; 13. ((heart-assist or vascular-assist or ventricular-assist) adj (device* or pump*)).mp.; 14. (device adj therapy).tw.; 15. (ventricular adj2 device*).tw.; 16. ((VAD or LVAD) and device*).tw.; 17. (artificial adj1 ventricle*).mp.; 18. exp Defibrillators, Implantable/; 19. ((ICD or ICDs) and implantable).tw.; 20. (implantable adj2 defibrillator*).mp.; 21. (internal adj2 defibrillator*).mp.; 22. ((external adj2 defibrillator*) not aed).mp.; 23. (implantable adj1 cardiac adj1 device*).mp.; 24. cardioverter-defibrillator*.mp.; 25. exp Cardiac Pacing, Artificial/; 26. (artificial adj pacing).mp.; 27. ((cardiac or heart) adj resynchroni?ation$).mp.; 28. ((biventricular or dual-chamber or single-chamber) adj1 (pacing or pacer or stimulat$)).mp.; 29. ((mechanical adj circulatory adj support adj system*) or MCSS).tw.; 30. or/7-29; 31. choice behavior/; 32. decisionmaking/; 33. decision support techniques/; 34. decision support systems, clinical/; 35. patient preference/; 36. informed consent/; 37. ((informed adj1 consent) or consent*).tw.; 38. (decision adj (support or aid* or process* or tool*)).tw.; 39. proxy/; 40. (proxy or proxies).tw.; 41. or/31-40; 42. and/6,41; 43. and/30,41; 44. patient participation/; 45. personal autonomy/; 46. cooperative behavior/; 47. communication/ or (communication* or discussion* or conversation*).tw.; 48. educational technology/; 49. (decision$ or choice$ or choose or preference$).tw.; 50. exp health education/; 51. Health Knowledge, Attitudes, Practice/; 52. Professional-Family Relations/; 53. ((patient$ or consumer$) adj2 (decision$ or choice$ or preference$ or participation)).tw.; 54. ((women or men) adj2 (decision$ or choice$ or preference$ or participation)).tw.; 55. ((personal or interpersonal or individual$) adj2 (decision$ or choice$ or preference$ or participat$)).tw.; 56. (shared adj2 decision adj2 making).tw.; 57. (decision adj (support or aid* or process* or tool*)).tw.; 58. (third adj party adj consent).tw.; 59. (proxy or proxies).tw.; 60. (informed adj1 choice).tw.; 61. exp Patient Education as Topic/mt [Methods]; 62. or/44-61; 63. and/6,62; 64. and/30,62; 65. and/6,30,62; 66. Health Knowledge, Attitudes, Practice/; 67. Treatment refusal/es, st, td; 68. Withholding treatment/; 69. “Dissent and disputes”/; 70. medical futility/; 71. advance care planning/es, st, mt, td; 72. terminal care/es, mt, px, st, td; 73. ethics, medical/; 74. social responsibility/; 75. (ethics or ethical).tw.; 76. (barriers or barrier).tw.; 77. exp depression/ or (depression or depressed or depressive).tw.; 78. exp anxiety/ or anxiety.tw.; 79. (deactivation or deactivating or deactivate*).tw.; 80. exp pain/ or pain*.tw.; 81. (cultur* or customs or belief*).tw.; 82. age factors/ or aged/ or (aged or elderly).tw.; 83. gender/ or gender.tw.; 84. or/66-83; 85. and/6,84; 86. and/6,30,84; 87. randomized controlled trial.pt.; 88. controlled clinical trial.pt.; 89. random$.ab.; 90. trial.tw.; 91. or/87-90; 92. (humans or human or adult or adults).hw,sh.; 93. and/91-92; 94. and/42,93; 95. and/43,93; 96. quasi-experimental.tw.; 97. (pre-test or post-test).mp.; 98. or/96-97; 99. and/42,98; 100. and/43,98; 101. or/94-95,99-100; 102. cohort studies/; 103. longitudinal studies/; 104. prospective studies/; 105. retrospective studies/; 106. comparative study.pt.; 107. (observation$ or prospectiv$ or retrospectiv$ or cohort$ or control$ or volunteer$ or evaluat$ or compar$ or longitudinal or long term or long-term or longterm or followup or follow up or follow-up).mp. and (study or studies or trial$).tw,sh,pt.; 108. exp Evaluation Studies/; 109. (survey* or questionnaire* or pre-test* or post-test*).mp.; 110. (observation adj stud*).mp.; 111. or/102-110; 112. (humans or human or adult or adults).hw,sh.; 113. and/111-112; 114. and/63,113; 115. and/64,113; 116. and/65,113; 117. and/85,113; 118. and/86,113; 119. and/63,93; 120. and/64,93; 121. and/65,93; 122. or/119-121; 123. or/101,122; 124. limit 123 to (english language and yr=“1990 -Current”); 125. or/114-118; 126. limit 125 to (english language and yr=“1990 -Current”); 127. limit 126 to humans

Table A–2 EMBASE–Ovid Version

Limits: trials, observational/qualitative studies; English only, 1990 – present Date searched: 7Dec10 Results: 370 trials; 2997 observational/qualitative studies
1. exp Pacemaker, Artificial/; 2. ((artificial or cardiac) adj2 pacemaker*).mp.; 3. pacemaker*.tw.; 4. exp Heart-Assist Devices/; 5. ((heart-assist or vascular-assist or ventricular-assist) adj (device* or pump*)).mp.; 6. (artificial adj1 ventricle*).mp.; 7. exp Defibrillators, Implantable/; 8. (implantable adj2 defibrillator*).mp.; 9. (implantable adj1 cardiac adj1 device*).mp.; 10. ((ICD or ICDs) and implantable).tw.; 11. ((external adj2 defibrillator*) not aed).mp.; 12. cardioverter-defibrillator*.mp.; 13. exp Cardiac Pacing, Artificial/; 14. (artificial adj pacing).mp.; 15. ((cardiac or heart) adj resynchroni?ation$).mp.; 16. ((biventricular or dual-chamber or single-chamber) adj1 (pacing or pacer or stimulat$)).mp.; 17. ((mechanical adj circulatory adj support adj system*) or MCSS).tw.; 18. ((VAD or LVAD) and device*).tw.; 19. or/1-18; 20. choice behavior/; 21. decisionmaking/; 22. decision theory/; 23. decision support techniques/; 24. decision support systems, clinical/; 25. patient preference/; 26. patient attitude/; 27. patient participation/; 28. educational technology/; 29. (decision$ or choice$ or choose or preference$).tw.; 30. (decision adj (support or aid* or process* or tool*)).tw.; 31. ((informed adj1 consent) or consent*).tw.; 32. (proxy or proxies).tw.; 33. or/20-32; 34. cooperative behavior/ or (cooperative adj behavio?r).tw.; 35. personal autonomy/ or (personal adj autonomy).tw.; 36. Health Knowledge, Attitudes, Practice/; 37. informed consent.tw,hw.; 38. communication/ or (communication* or discussion* or conversation*).tw.; 39. Professional-Family Relations/; 40. ((patient$ or consumer$) adj1 (decision$ or choice or preference or participation)).tw.; 41. ((women or men) adj1 (decision$ or choice or preference or participation)).tw.; 42. ((personal or interpersonal or individual) adj (decision$ or choice or preference$ or participat$)).tw.; 43. (shared adj decision adj making).tw.; 44. (decision adj (support or aid* or process* or tool*)).tw.; 45. (informed adj1 choice).tw.; 46. Patient Education/ or (patient adj education).mp.; 47. treatment refusal/ or (treatment adj refusal).tw.; 48. withholding treatment/ or (withholding adj treatment*).tw.; 49. “Dissent and disputes”/; 50. medical futility/; 51. ethics, medical/ or (ethics or ethical).tw.; 52. (barriers or barrier).tw.; 53. (deactivation or deactivating or deactivate*).tw.; 54. exp anxiety/ or anxiety.tw.; 55. exp pain/ or pain*.tw.; 56. (cultur* or customs or belief*).tw.; 57. exp depression/ or (depression or depressed or depressive).tw.; 58. gender/ or gender.tw.; 59. age factors/ or aged/ or (aged or elderly).tw.; 60. or/34-59; 61. clinical trial/; 62. clinical trial:.mp.; 63. random:.tw.; 64. placebo:.mp.; 65. double-blind:.tw.; 66. or/61-65; 67. and/19,33,66; 68. limit 67 to (human and english language and yr=“1990 -Current”); 69. and/19,60,66; 70. (pre-test or post-test).mp.; 71. quasi-experimental.tw.; 72. or/70-71; 73. and/19,33,72; 74. and/19,60,72; 75. or/73-74; 76. limit 75 to (human and english language and yr=“1990 -Current”); 77. cohort analysis/; 78. longitudinal study/; 79. follow-up/; 80. prospective study/; 81. retrospective study/; 82. (observation$ or prospectiv$ or retrospectiv$ or cohort$ or control$ or volunteer$ or evaluat$ or compar$ or longitudinal or long term or long-term or longterm or followup or follow up or follow-up).mp. and (study or studies or trial$).tw,sh.; 83. exp Evaluation Studies/; 84. (pre-test or post-test).mp.; 85. (observation adj stud*).mp.; 86. or/77-85; 87. and/19,60,86; 88. and/19,33,86; 89. or/87-88; 90. limit 89 to (human and english language and yr=“1990 -Current”); 91. or/67,76; 92. and/19,33,60,86; 93. 88 or 92; 94. or/1,7-8; 95. 87 and 94; 96. limit 95 to (human and english language and yr=“1990 -Current”)

Table A–3 CENTRAL

Limits: 1990 – present. Trials only Date Searched: 08Dec10 Results: 158 trials
1. Heart Failure/th; 2. heart diseases/th; 3. Arrhythmias, Cardiac/th; 4. Myocardial ischemia/th; 5. Ventricular Dysfunction, Left/th; 6. or/1-5; 7. exp Pacemaker, Artificial/; 8. ((artificial or cardiac) adj2 pacemaker*).mp.; 9. pacemaker*.tw.; 10. exp Heart-Assist Devices/; 11. heart conduction system/; 12. ((heart-assist or vascular-assist or ventricular-assist) adj (device* or pump*)).mp.; 13. (artificial adj1 ventricle*).mp.; 14. (device adj therapy).tw.; 15. (ventricular adj2 device*).tw.; 16. ((VAD or LVAD) and device*).tw.; 17. exp Defibrillators, Implantable/; 18. (implantable adj2 defibrillator*).mp.; 19. (implantable adj1 cardiac adj1 device*).mp.; 20. ((ICD or ICDs) and implantable).tw.; 21. ((external adj2 defibrillator*) not aed).mp.; 22. cardioverter-defibrillator*.mp.; 23. exp Cardiac Pacing, Artificial/; 24. (artificial adj pacing).mp.; 25. ((cardiac or heart) adj resynchroni?ation$).mp.; 26. ((biventricular or dual-chamber or single-chamber) adj1 (pacing or pacer or stimulat$)).mp.; 27. ((mechanical adj circulatory adj support adj system*) or MCSS).tw.; 28. or/7-27; 29. or/6,28; 30. choice behavior/; 31. decisionmaking/; 32. decision support techniques/; 33. decision support systems, clinical/; 34. patient preference/; 35. informed consent/; 36. Third-Party consent/; 37. ((informed adj1 consent) or consent*).tw.; 38. proxy/; 39. (proxy or proxies).tw.; 40. patient participation/; 41. personal autonomy/; 42. cooperative behavior/; 43. communication/ or (communication* or discussion* or conversation*).tw.; 44. educational technology/; 45. (decision$ or choice$ or choose or preference$).tw.; 46. (decision adj (support or aid* or process* or tool*)).tw.; 47. or/30-46; 48. Health Knowledge, Attitudes, Practice/; 49. Professional-Family Relations/; 50. ((patient$ or consumer$) adj2 (decision$ or choice$ or preference$ or participation)).tw.; 51. ((women or men) adj2 (decision$ or choice$ or preference$ or participation)).tw.; 52. ((personal or interpersonal or individual) adj2 (decision$ or choice$ or preference$ or participat$)).tw.; 53. (shared adj2 decision adj2 making).tw.; 54. ((decision adj2 (support or aid* or process* or tool*)) or decision*).tw.; 55. (third adj party adj consent).tw.; 56. (proxy or proxies).tw.; 57. (informed adj2 (choice* or consent*)).tw.; 58. exp Patient Education as Topic/ or (patient adj education).tw.; 59. treatment refusal/ or (treatment adj refusal).tw.; 60. withholding treatment/ or (withholding adj treatment*).tw.; 61. “Dissent and disputes”/; 62. medical futility/; 63. ethics, medical/ or (ethics or ethical).tw.; 64. (barriers or barrier).tw.; 65. (deactivation or deactivating or deactivate*).tw.; 66. or/48-65; 67. and/29,47; 68. and/29,66; 69. or/67-68; 70. limit 69 to yr=“1990 -Current”

Table A–4 PsycINFO

Limits: 1990 – present. Date searched: 9Dec10 Results: 9 trials; 112 qualitative results
1. exp “Fibrillation (Heart)”/; 2. exp Artificial Pacemakers/; 3. ((artificial or cardiac) adj2 pacemaker*).mp.; 4. pacemaker*.tw.; 5. ((heart-assist or vascular-assist or ventricular-assist) adj (device* or pump*)).mp.; 6. (artificial adj1 ventricle*).mp.; 7. (implantable adj2 defibrillator*).mp.; 8. (implantable adj1 cardiac adj1 device*).mp.; 9. ((ICD or ICDs) and implantable).tw.; 10. ((external adj2 defibrillator*) not aed).mp.; 11. cardioverter-defibrillator*.mp.; 12. (artificial adj pacing).mp.; 13. ((cardiac or heart) adj resynchroni?ation$).mp.; 14. ((biventricular or dual-chamber or single-chamber) adj1 (pacing or pacer or stimulat$)).mp.; 15. ((mechanical adj circulatory adj support adj system*) or MCSS).tw.; 16. ((VAD or LVAD) and device*).tw.; 17. or/1-16; 18. (decision$ or choice$ or choose or preference$).tw.; 19. (decision adj (support or aid* or process* or tool*)).tw.; 20. ((informed adj1 consent) or consent*).tw.; 21. (proxy or proxies).tw.; 22. computer assisted instruction/; 23. or/18-22; 24. cooperative behavior/ or (cooperative adj behavio?r).tw.; 25. health knowledge/; 26. client education/; 27. exp social support/; 28. exp psychological needs/; 29. exp psychological effects/; 30. personal autonomy/ or (personal adj autonomy).tw.; 31. informed consent.tw,hw.; 32. communication/ or (communication* or discussion* or conversation*).tw.; 33. ((patient$ or consumer$) adj1 (decision$ or choice or preference or participation)).tw.; 34. ((women or men) adj1 (decision$ or choice or preference or participation)).tw.; 35. ((personal or interpersonal or individual) adj (decision$ or choice or preference$ or participat$)).tw.; 36. (shared adj decision adj making).tw.; 37. (decision adj (support or aid* or process* or tool*)).tw.; 38. (informed adj1 choice).tw.; 39. Patient Education/ or (patient adj education).mp.; 40. treatment refusal/ or (treatment adj refusal).tw.; 41. withholding treatment/ or (withholding adj treatment*).tw.; 42. ethics, medical/ or bioethics/ or (ethics or ethical).tw.; 43. (barriers or barrier).tw.; 44. anxiety/ or anxiety.tw.; 45. exp pain/ or pain*.tw.; 46. (cultur* or customs or belief*).tw.; 47. exp depression/ or (depression or depressed or depressive).tw.; 48. gender/ or gender.tw.; 49. age factors/ or aged/ or (aged or elderly).tw.; 50. exp distress/; 51. exp caregiver burden/; 52. (deactivation or deactivating or deactivate*).tw.; 53. or/24-52; 54. clinical trial/; 55. clinical trial:.mp.; 56. random:.tw.; 57. placebo:.mp.; 58. double-blind:.tw.; 59. or/54-58; 60. and/17,23,59; 61. limit 60 to (human and english language and yr=“1990 -Current”); 62. and/17,53,59; 63. (pre-test or post-test).mp.; 64. quasi-experimental.tw.; 65. or/63-64; 66. and/17,23,65; 67. and/17,53,65; 68. or/66-67; 69. limit 68 to (human and english language and yr=“1990 -Current”); 70. cohort analysis/; 71. longitudinal studies/; 72. follow-up studies/; 73. prospective studies/; 74. retrospective studies/; 75. observation methods/; 76. (observation$ or prospectiv$ or retrospectiv$ or cohort$ or control$ or volunteer$ or evaluat$ or compar$ or longitudinal or long term or long-term or longterm or followup or follow up or follow-up).mp. and (study or studies or trial$).tw,sh.; 77. (pre-test or post-test).mp.; 78. (observation adj stud*).mp.; 79. or/70-78; 80. and/17,53,79; 81. and/17,23,79; 82. or/80-81; 83. limit 82 to (human and english language and yr=“1990 -Current”)

Table A–5 CINAHL

Limits: 1990 – present. Date searched: 13Dec10 Results: 403 trials; 1628 qualitative results
S37 S26 and S36; S36 (MH “Clinical Trials+”); S35 S26 and S34; S34 S27 or S28 or S29 or S30 or S31 or S32 or S33; S33 TX observational study or TX observational studies; S32 (MH “Retrospective Panel Studies”) OR retrospective study; S31 TX comparative study or TX comparative studies; S30 (MH “Nonexperimental Studies”); S29 TX pre-test Or post-test; S28 (MH “Evaluation Research”); S27 (MH “Prospective Studies+”) OR (MH “Concurrent Prospective Studies”); S26 S10 and S25; S25 S11 or S12 or S13 or S14 or S15 or S16 or S17 or S18 or S19 or S20 or S21 or S22 or S23 or S24; S24 (MH “Patient Education+”) and TX ( decision* or choice* pr preference* ); S23 (MH “Decision Support Systems, Management”) OR (MH “Decision Support Systems, Clinical”) OR Decision support system; S22 TX shared decisionmaking; S21 TX (patient preference* or patient choice* or patient participation or patient decision*) or TX (consumer decision* or consumer choice* or consumer preference* or consumer participation*); S20 (MH “Decisionmaking, Family”) OR (MH “Decisionmaking, Ethical”) OR (MH “Decisionmaking, Patient+”); S19 TX third party consent or TX Proxy or TX proxies; S18 TX informed consent or TX consent; S17 (MH “Consumer Participation”); S16 (MH “Consent”); S15 (MH “Educational Technology”); S14 TX (choice* or decision$ or choose or preference*); S13 (MH “Help Seeking Behavior”); S12 (MH “Information Seeking Behavior”); S11 (MH “Decisionmaking+”); S10 S1 or S2 or S3 or S4 or S5 or S6 or S7 or S8 or S9; S9 (MH “Heart Assist Devices”); S8 TX cardiac resynchronization or TX cardiac resynchronisation or TX heart resynchronization or TX heart resynchronisation; S7 (MH “Cardiac Pacing, Artificial”); S6 TX cardioverter-defibrillator; S5 implantable defibrillator* or implantable cardiac device*; S4 (MH “Defibrillators, Implantable”); S3 TX ( heart-assist device* or heart-assist pump* ) or ( cardiac-assist device* or cardiac-assist pump* ) or ( ventricular-assist device* OR ventricular-assist pump* ); S2 TX pacemaker*; S1 (MH “Pacemaker, Artificial”)

Table A–6 Medline focused search

AHRQ device tool project _MEDLINE - new focused search_8Feb11 MEDLINE - 8Feb11 - RCT filter and no qual filter
1. heart failure/th; 2. heart diseases/th; 3. Arrhythmias, cardiac/th; 4. Myocardial ischemia/th; 5. Ventricular dysfunction, left/th; 6. or/1-5; 7. exp Pacemaker, Artificial/; 8. ((artificial or cardiac) adj2 pacemaker*).mp.; 9. pacemaker*.tw.; 10. (PPM and pacemaker*).tw.; 11. exp Heart-Assist Devices/; 12. heart conduction system/; 13. ((heart-assist or vascular-assist or ventricular-assist) adj (device* or pump*)).mp.; 14. (device adj therapy).tw.; 15. (ventricular adj2 device*).tw.; 16. ((VAD or LVAD or CIED) and device*).tw.; 17. (artificial adj1 ventricle*).mp.; 18. exp Defibrillators, Implantable/; 19. ((ICD or ICDs or CIED or CIEDs) and implantable).tw.; 20. (implantable adj2 defibrillator*).mp.; 21. (internal adj2 defibrillator*).mp.; 22. ((external adj2 defibrillator*) not aed).mp.; 23. ((implantable adj3 cardiac adj3 device*) or (implantable adj3 cardiovascular adj3 device*)).mp.; 24. cardioverter-defibrillator*.mp.; 25. exp Cardiac Pacing, Artificial/; 26. (artificial adj pacing).mp.; 27. ((cardiac or heart) adj resynchroni?ation$).mp.; 28. ((biventricular or dual-chamber or single-chamber) adj1 (pacing or pacer or stimulat$)).mp.; 29. ((mechanical adj circulatory adj support adj system*) or MCSS).tw.; 30. or/7-29; 31. Treatment refusal/; 32. Withholding treatment/; 33. (withdrawal or withdrawing).tw.; 34. exp device removal/; 35. (device* adj1 remov*).tw.; 36. (deactivation or deactivating or deactivate*).tw.; 37. medical futility/; 38. advance care planning/; 39. terminal care/; 40. hospice care/; 41. palliative care/; 42. ((palliative or hospice or terminal) adj care).tw.; 43. terminally ill/; 44. ethics, medical/; 45. (ethics or ethic or ethical).tw.; 46. medicolegal.tw.; 47. exp euthanasia/; 48. suicide, assisted/; 49. (end-of-life or “end of life”).tw.; 50. ((ICD adj2 discharge*) and distress*).tw.; 51. or/31-50; 52. and/30,51; 53. randomized controlled trial.pt.; 54. controlled clinical trial.pt.; 55. random$.ab.; 56. trial.tw.; 57. or/53-56; 58. (humans or human or adult or adults).hw,sh.; 59. and/57-58; 60. and/30,51,59; 61. 52 not 60

Table A–7 EMBASE focused search

AHRQ device tool project _EMBASE - new focused search_2Feb11 EMBASE -8Feb11 - RCT filter and no qual filter
1. artificial heart pacemaker/; 2. defibrillator/; 3. pacemaker*.tw.; 4. Heart Assist Device/; 5. (artificial adj1 ventricle*).tw.; 6. (implantable adj2 defibrillator*).tw.; 7. (implantable adj2 device*).tw.; 8. ((ICD or ICDs or CIED or CIEDs) and implantable).tw.; 9. cardioverter-defibrillator*.tw.; 10. (artificial adj pacing).tw.; 11. ((cardiac adj resynchroni?ation*) or (heart adj resynchroni?ation)).tw.; 12. or/1-11; 13. treatment refusal/; 14. treatment withdrawal/; 15. (withdrawal or withdrawing).tw.; 16. device removal/; 17. (device* adj1 remov*).tw.; 18. (deactivation or deactivating or deactivate*).tw.; 19. medical ethics/; 20. (ethics or ethic or ethical).tw.; 21. medicolegal.tw.; 22. exp terminal care/; 23. hospice care/; 24. palliative therapy/; 25. ((palliative or hospice or terminal) adj care).tw.; 26. terminally ill patient/; 27. exp euthanasia/; 28. assisted suicide/; 29. ((ICD* adj2 discharge*) and distress*).tw.; 30. ((ICD* adj2 discharge*) and inappropriate).tw.; 31. end-of-life.ti.; 32. or/13-31; 33. and/12,32; 34. clinical trial/; 35. clinical trial:.mp.; 36. random:.tw.; 37. placebo:.mp.; 38. double-blind:.tw.; 39. or/34-38; 40. and/12,32,39; 41. 33 not 40

Table A–8 CENTRAL focused search

AHRQ device tool project _CENTRAL - new focused search_3Feb11 CENTRAL - 3Feb11 - drafted secondary focused search - devices AND end of life
1. exp Pacemaker, Artificial/; 2. ((artificial or cardiac) adj2 pacemaker*).mp.; 3. pacemaker*.tw.; 4. exp Heart-Assist Devices/; 5. Heart Conduction System/; 6. ((heart-assist or vascular-assist or ventricular-assist) adj (device* or pump*)).mp.; 7. (device adj therap*).tw.; 8. (ventricular adj2 device*).tw.; 9. ((VAD or LVAD or CIED) and device*).tw.; 10. (artificial adj1 ventricle*).mp.; 11. Defibrillators, Implantable/; 12. ((ICD or ICDs or CIED or CIEDs) and implantable).tw.; 13. (implantable adj2 defibrillator*).mp.; 14. (internal adj2 defibrillator*).mp.; 15. ((external adj2 defibrillator*) not AED).tw.; 16. ((implantable adj3 cardiac adj3 device) or (implantable adj3 cardiovascular adj3 device*)).mp.; 17. cardioverter-defibrillator*.mp.; 18. exp Cardiac Pacing, Artificial/; 19. ((cardiac or heart) adj resynchroni?ation*).mp.; 20. ((biventricular or dual-chamber or single-chamber) adj1 (pacing or pacer or stimulat$)).mp.; 21. or/1-20; 22. exp Treatment Refusal/; 23. exp Withholding Treatment/; 24. Device Removal/; 25. (device* adj1 remov*).tw.; 26. (withdrawal or withdrawing).tw.; 27. (deactivation or deactivating or deactivate*).tw.; 28. Medical Futility/; 29. exp Advance Care Planning/; 30. Terminal Care/; 31. hospice care/; 32. terminally ill/; 33. Ethics, Medical/; 34. (ethics or ethic or ethical).tw.; 35. medicolegal.tw.; 36. exp euthanasia/; 37. (end-of-life or “end of life”).tw.; 38. ((ICD adj2 discharge*) and distress*).tw.; 39. or/22-38; 40. and/21,39

Table A–9 PsycINFO focused search

AHRQ device tool project _PsycINFO - new focused search_3Feb11 PsycINFO - 3Feb11 - drafted secondary focused search - devices AND end of life
1. exp “Fibrillation (Heart)”/; 2. exp Artificial Pacemakers/; 3. ((artificial or cardiac) adj2 pacemaker*).mp.; 4. pacemaker*.tw.; 5. ((heart-assist or vascular-assist or ventricular-assist) adj (device* or pump*)).mp.; 6. (implantable adj2 defibrillator*).mp.; 7. (implantable adj2 cardiac adj2 device*).mp.; 8. ((ICD or ICDs) and implantable).tw.; 9. ((external adj2 defibrillator*) not aed).mp.; 10. ((cardiac or heart) adj resynchroni?ation$).mp.; 11. cardioverter-defibrillator*.mp.; 12. ((biventricular or dual-chamber or single-chamber) adj1 (pacing or pacer or stimulat$)).mp.; 13. ((VAD or LVAD or CIED or ICD) and device*).tw.; 14. or/1-13; 15. exp Treatment Refusal/; 16. exp Treatment Withholding/; 17. life sustaining treatment/; 18. (withdrawal or withdrawing).tw.; 19. (device* adj1 remov*).tw.; 20. (deactivation or deactivating or deactivate*).tw.; 21. advance directives/; 22. exp Terminally Ill Patients/; 23. exp Hospice/; 24. exp Palliative Care/; 25. ((palliative or hospice or terminal) adj care).tw.; 26. ((palliative or hospice or terminal) adj treatment).tw.; 27. ((palliative or hospice or terminal) adj setting).tw.; 28. exp Bioethics/; 29. (ethics or ethic or ethical).tw.; 30. medicolegal.tw.; 31. euthanasia/; 32. exp Assisted Suicide/; 33. exp Death Attitudes/; 34. exp “Death and Dying”/; 35. (end-of-life or “end of life”).tw.; 36. ((defibrillator adj2 discharge*) and (anxiety* or fear* or inappropriate or stress or distress)).tw.; 37. ((ICD adj2 discharge*) and (anxiety* or fear* or inappropriate or stress or distress)).tw.; 38. ((device adj2 discharge*) and (anxiety* or fear* or inappropriate or stress or distress)).tw.; 39. or/15-38; 40. and/14,39