# List of Abbreviations

AHRQ: Agency for Healthcare Research and Quality
AMA: American Medical Association
CRT: Cardiac resynchronization therapy
ECD: Electronic cardiac device
HRS: Heart Rhythm Society
ICD: Implantable cardioverter-defibrillator
KQ: Key question
NRCT: Nonrandomized controlled trial
RCT: Randomized controlled trial
VAD: Ventricular assist device