# Results

Our searches identified a total of 10,866 abstracts, of which we screened 348 in full text and included 84 articles (Figure 2). Appendix B lists the studies that were excluded in full text. There were 31 articles that described 13 randomized controlled trials (RCTs) and 4 nonrandomized comparative studies (nRCSs) that address Key Questions 1 and 3. For Key Question 2, there were 59 articles that included 37 independent study cohorts of patients with ICD, including 4 RCTs that compared different types of ICDs. Six articles (Five studies) were included in both Key Questions 1 and 2.

Figure 2 Literature Flow Diagram

ICD = implanted cardioverter defibrillator, nRCSs = nonrandomized comparative studies, RCTs = randomized controlled trials.

Studies could have had more than one reason for exclusion but only one reason for each is listed here.

* Includes multiple publications (articles) derived from the same studies. Five articles on 4 studies provided data for Key Questions 1 and 2.

Figure 2 is a flow chart that summarizes the study retrieval and selection process of articles relevant to the three key questions. The figure displays the same information as enumerated in the first paragraph of the Results section. In addition, the figure includes the following reasons that the 264 full-text articles that were excluded: ineligible study design (n=66), no outcomes of interest (n=43), not population of interest (n=37),mixed primary & secondary prevention, no adverse events (n=33), secondary prevention only (n=31), adverse event paper with N<500 (n=13), adverse event paper published before 2002 (n=10), other (n=31).

Of note, under Key Question 1, we have incorporated Key Question 1c (on subgroups) into both Key Questions 1a (ICD vs. no ICD) and 1b (ICD vs. ICD).

The list following this paragraph includes all studies included for Key Question 1, with their acronyms defined. In the Discussion section, we explain why several well-known ICD trials did not meet eligibility criteria.

AMIOVERT | Amiodarone Versus Implantable Cardioverter-Defibrillator: Randomized Trial in Patients With Nonischemic Dilated Cardiomyopathy and Asymptomatic Nonsustained Ventricular Tachycardia
CABG-Patch | Coronary Artery Bypass Graft Patch Trial
CAT | Cardiomyopathy Trial
Chan 2009
COMPANION | Comparison of Medical Therapy, Pacing and Defibrillation in Heart Failure
DEFINITE | Defibrillators in Nonischemic Cardiomyopathy Treatment Evaluation
Diab 2011
DINAMIT | Defibrillator in Acute Myocardial Infarction Trial
Fonarow 2000
IRIS | Immediate Risk Stratification Improves Survival
MADIT | Multicenter Automatic Defibrillator Implantation Trial
MADIT II | Multicenter Automatic Defibrillator Implantation Trial II
MADIT-CRT | Multicenter Automatic Defibrillator Implantation Trial with Cardiac Resynchronization Therapy
MENDMI | Prevention of Myocardial Enlargement and Dilation Post Myocardial Infarction Study
Mezu 2011
OPTIMIZE-HF/GWTG-HF | Organized Program to Initiate Lifesaving Treatment in Hospitalized Patients with Heart Failure and Get With the Guidelines-Heart Failure
RAFT | Resynchronization-Defibrillation for Ambulatory Heart Failure
SCD-HeFT | Sudden Cardiac Death in Heart Failure Trial

## Key Questions 1a & 1c In Candidates for ICD Implantation for Primary Prevention of SCD, What Are the Effects of ICD Therapy Compared with No ICD Therapy on Clinical Outcomes and Patient-Reported Outcomes? How Do Outcomes Vary Within Subgroups?

For Key Questions 1a and 1c, we included studies that compared ICD use with no ICD use, with or without concomitant CRT or ATP in adults being treated for primary prevention of SCD. Except as noted, we did not distinguish between studies that compared ICD with no ICD (both arms with or without antiarrhythmic drugs) and studies that compared ICD alone with antiarrhythmic drugs. The findings and strength of evidence for outcomes with sufficient evidence for the comparison of ICD versus no ICD are summarized in Table 3.

Table 3 Summary of findings for ICD vs. no ICD

Outcome | Study Design: No. Studies (N) | Findings | Strength of Evidence
All-cause mortality | ICD vs. no ICD RCT: 10 (8,606) nRCS: 4 (5,949) | - ICD use as primary prevention for patients who meet the current practice criteria (no recent MI, no concurrent coronary revascularization) reduces the risk of all-cause mortality over the course of 3 to 7 years after implantation: HR = 0.69 (95% CI 0.60, 0.79). The benefit of ICD appears fairly stable over time. Across trials, the range of NNT to prevent one death was 6.2 to 22 at 3 to 7 years, with wide 95% CIs.; - There is indirect evidence across studies that patients with recent MIs (<30-40 days), on average, do not benefit from ICD, in contrast with patients with more distant MIs.; - Within-study subgroup analyses fail to support whether the value of ICD placement differs in other subgroups of patients, including by sex or age, or based on different characteristics of facilities where ICDs are implanted. | High
Sudden cardiac death | ICD vs. no ICD RCT: 7 (4,093) nRCS: 2 (1,115) | - ICD use as primary prevention for patients who meet the current practice criteria (no recent MI, no concurrent coronary revascularization) reduces the risk of SCD over the course of 2 to 6 years after implantation: HR = 0.37 (95% CI 0.26, 0.52). There is insufficient evidence to evaluate the course of the effect over time. Across trials, the range of NNT to prevent one SCD was approximately 2.0 to 11.; - Within-study subgroup analyses fail to support whether the value of ICD placement differs in subgroups of patients or based on different characteristics of facilities where ICDs are implanted. | High
Quality of life | ICD vs. no ICD RCT: 3 (1,825) | - The evidence fails to show a consistent effect of ICD placement on quality of life.; - There is no evidence regarding subgroups. | Low

CI = confidence interval, CMS = Centers for Medicare and Medicaid Services, HR = hazard ratio, ICD = implantable cardioverter–defibrillator, MI = myocardial infarction, NNT = number-needed-to-treat, No. = number, nRCS = nonrandomized comparative study, RCT = randomized, controlled trial, SCD = sudden cardiac death.

We identified 10 RCTs (reported in 18 articles42,51,76,91-104) and 4 nRCSs105-108 (Table 4).

Table 4 ICD vs. no ICD: Study characteristics

Study Author Year PMID | Intervention (Control) | NYHA class | Ischemic | Non-ischemic | Nonsustained VT | %LVEF | Total N | Primary outcome | Duration followup | ICD type/No. of leads | Enrollment period
AMIOVIRT Strickberger 2003 12767651 | ICD (Amiodarone) | I, II, III | No | Yes | Yes | ≤35 | 103 | Death, all-cause | 5 y | nd | 8/1996-9/2000
CABG-Patch Bigger 1997 9371853 | ICD (No ICD) | NYHA not a criterion | Yes | No | No | <36 | 900 | Death, all-cause | 4 y mean 32 ± 16 mo (2.67 y) | nd | Pilot began 1990 with full-scale study started in 1993
CAT Bansch 2002 11914254 | ICD (Control) | II, III | No | Yes | No | ≤30 | 104 | Death, all-cause at 1 y | 6 y | nd | 5/1991-3/1997
Chan 2009 20031808 | ICD (No ICD) | NYHA not a criterion | Yes | Yes | No | ≤35 | 965 | Death, all-cause | 5 y | nd | 3/2001-6/2005
COMPANION Bristow 2004 15152059 | ICD + CRT (No ICD)^*^ | III, IV | Yes | Yes | No | ≤35 | 1520 | Death from or hospitalization for any cause | 1080 d (2.95 y) median 14 mo (weighted average of CRT-D and control groups) | Multi-chamber | 1/2000-11/2002
DEFINITE Kadish 2004 15152060 | ICD (No ICD) | I, II, III | No | Yes | Yes | <36 | 458 | Death, all-cause | 5 y mean 29 ± 14.4 mo (2.42 y) | Single-chamber | 1998-2002 (randomization date)
DINAMIT Hohnloser 2004 15590950 | ICD (No ICD) | I, II, III | Yes | No | No | ≤35 | 674 | Death, all-cause | 4 y mean 2.5 y | Single-chamber | 1998-nd (last follow-up 9/2003)
Fonarow 2000 10760339 | ICD (Control) | III, IV | No | Yes | No | <35 | 147 | nd | mean 22 ± 26 mo | nd | 1/1988-1/1997
IRIS Steinbeck 2009 19812399 | ICD (No ICD) | I, II, III | Yes | No | Yes | ≤40 | 898 | Death, all-cause | 6 y mean 37 mo | nd | 6/9/1999-10/15/2007
MADIT Moss 1996 8960472 | ICD (No ICD) | I, II, III | Yes | No | Yes | ≤35 | 196 | Death, all-cause | 5 y mean 27 mo | Single-chamber | 1990-nd (trial stopped in 1996)
MADIT II Moss 2002 11907286 | ICD (No ICD) | I, II, III | Yes | No | No | ≤30 | 1232 | Death, all-cause | mean 20 mo range 6 d-53 mo | nd | 7/11/1997-nd
Mezu 2011 21640321 | ICD (No ICD) | I, II, III | Yes | Yes | No | ≤35 | 152 | Death, all-cause | 4 y mean 2.3 y | nd | 1/2000-12/2008
OPTIMIZE-HF and GWTG-HF Hernandez 2010 20009044 | ICD (No ICD) | NYHA not a criterion | No | No | No | ≤35 | 4685 | Death, all-cause | 3 y | nd | 2003-2006
SCD-HeFT Bardy 2005 15659722 | ICD (no ICD/placebo)^#^ | II or III | Yes | Yes | Yes | ≤35 | 2521 | Death, all-cause | 6 y median (survivors) 45.5 mo | Single-chamber | 9/16/1997-7/18/2001 (randomization date)

* The CRT-P arm of COMPANION study was not used for the meta-analysis

# The amiodarone arm of SCD-HeFT was not used for the meta-analysis

AMIOVERT = Amiodarone versus Implantable Cardioverter-Defibrillator Randomized Trial, CABG-Patch = Coronary Artery Bypass Graft Patch, CAT = Cardiomyopathy Trial, COMPANION = Comparison of Medical Therapy, Pacing and Defibrillation in Heart Failure, CRT = cardiac resynchronization therapy, d = day, DEFINITE = Defibrillators in Nonischemic Cardiomyopathy Treatment Evaluation, DINAMIT = Defibrillator in Acute Myocardial Infarction Trial, GWTG-HF = Get With the Guidelines-Heart Failure, ICD = implantable cardiac defibrillator, IRIS = Immediate Risk Stratification Improves Survival, LV = left ventricular, MADIT = Multicenter Automatic Defibrillator Implantation Trial, mo = month, nd = not documented, NYHA = New York Heart Association, OPTIMIZE-HF = Organized Program to Initiate Lifesaving Treatment in Hospitalized Patients with Heart Failure, SCD-HeFT = Sudden Cardiac Death in Heart Failure Trial, VT = ventricular tachycardia, y = year

Among the 14 RCTs, 9 were assessed to be of good quality and 5 of fair quality (Figure 3, Appendix Table 8); 2 of these trials were further downgraded (to fair or poor quality) for outcomes other than all-cause mortality because outcome assessors were not blinded.92,94 Methodological concerns included high attrition rates (>20%),95 differential rates of attrition and/or crossover between study groups,51,94,95,99 and differences in the rates of use of beta blockers between the two study groups.51 Of note, all trials conducted intention-to-treat analyses.

Figure 3 Risk of bias for 13 RCTs of ICD vs. no ICD or vs. other ICD for primary prevention of SCD

The numbers within the bars represent the number of studies within each category.

Overall: Good, fair, or poor quality study

Randomization: What is the risk of selection bias (biased allocation to interventions) due to inadequate generation of a randomized sequence?

Allocation Concealment: What is the risk of selection bias (biased allocation to interventions) due to inadequate concealment of allocations before assignment?

Blinding: Outcome Assessor Blinding—or each main outcome or class of outcomes, what was the risk of detection bias due to knowledge of the allocated interventions by outcome assessment (lack of outcome assessor blinding)?

Attrition: For each main outcome or class of outcomes, what is the risk of attrition bias due to amount, nature, or handling of incomplete outcome data?

ITT: Intention-to-Treat—Were all randomized participants analyzed in the group to which they were allocated?

Base Similar: Groups Similarity—Were the groups similar at baseline regarding the most important prognostic indicators?

Cointervention: Were co-interventions avoided or similar?

Figure 3 is a bar chart enumerating how many studies were of good, fair, or poor quality overall and had low, unclear, or high risk of bias for 7 items. The specific risk of bias items are described in the figure legend. The figure displays the following: overall, 9 good, 5 fair; randomization 14 low risk of bias; allocation concealment 4 low, 10 unclear risk of bias; blinding 7 low, 4 unclear, 3 high risk of bias; attrition 12 low, 2 high risk of bias; ITT 14 low risk of bias; base similar 14 low risk of bias; cointervention 13 low, 1 high risk of bias.

We did not explicitly grade the methodological quality of the four nRCSs, though we included only studies that performed multivariable analyses.

The 14 studies were published from 1996 to 2011 and the patients' mean ages ranged from 48 to 86 years. The RCTs enrolled between 103 and 2,521 patients, and the nRCSs analyzed between 147 and 4,685 patients. The majority of patients in these studies were men with LVEF ranging from 21 to 28 percent. All four New York Heart Association (NYHA) classes were represented in the study samples. Two studies (one RCT95 and one nRCS106) included only patients with NYHA Class III or IV heart failure. The RCT enrolled approximately 84 percent Class III patients and the nRCS enrolled half Class III and half Class IV patients. The percentage of patients with diabetes ranged widely across the studies, from 5 to 63 percent. Additional information about the characteristics of the patients included in the studies is described under Key Question 3.

Of note, two of the trials that met eligibility criteria (IRIS and DINAMIT)98,102 included patients who would not meet current CMS criteria for an ICD because they were restricted to patients who had a recent MI (within 31 or 40 days). In a third trial, CABG-Patch,94 ICD implantation took place at the time of coronary artery bypass graft (CABG). These patients would also fall outside of the current clinical guidelines for implantation as well as guidelines for CMS coverage. Thus, the primary meta-analyses of the RCTs exclude these three trials, though they are included in tables, forest plots, and sensitivity analyses.

### All-Cause Mortality

All 10 RCTs and 4 nRCSs reported data on long-term all-cause mortality (Appendix Table 3). We meta-analyzed the RCT data, as shown in Figure 4. The studies followed patients for approximately 3 to7 years (mean followup durations of about 1.3 to 5.5 years). ICD implantation resulted in a lower risk (or hazard) of all-cause death (summary HR 0.69; 95% CI 0.60, 0.79) without statistical heterogeneity. The estimated NNTs to prevent one death for these studies (Table 8) ranged from 6.2 (95% CI 4.0, 18) to 22 (95% CI 2.3, infinite) at the longest durations of followup (3 to 7 years).

Figure 4 Random effects model meta-analysis of ICD vs. no ICD for all-cause mortality

CI = confidence interval; CRT-D = cardiac resynchronization therapy with a defibrillator; CRT-P = cardiac resynchronization therapy with a pacemaker (without a defibrillator); f/up = followup; HR = hazard ratio; ICD = implantable cardiac defibrillator; n/N = total events (deaths)/total analyzed. See page 16 for study acronyms.

* Values in brackets are medians; ∼ signifies approximate.

† Not included in meta-analyses (the alternative comparison for each study was the only comparison included in meta-analyses).

‡ Hazard ratio and confidence interval estimated from reported data.

§ The 8-year (maximum) followup of MADIT II (Barsheshet 2011) excluded because it analyzed an arbitrary subgroup of ICD group only.

¶ Differential use of beta blockers between ICD and amiodarone groups (but not between ICD and no ICD groups).

Figure 4 is a forest plot that displays the meta-analyzed hazard ratio of all-cause mortality with confidence intervals for individual trials. There are 10 trials in the forest plot (COMPANION, MADIT II, AMIOVIRT, MADIT, DEFINITE, DINAMIT, CABG-Patch, IRIS, SCD-HeFT, and CAT). For 2 trials (COMPANION and SCD-HeFT) there are also secondary comparisons (to alternative comparators) that are not included in the meta-analysis. The hazard ratios across studies range from 0.46 to 1.08. The maximum duration of followup ranges from 1000 days to 7 years. The mean duration of followup ranges from about 1.3 years to 5.5 years. Including only the 7 “typical” studies, the summary hazard ratio is 0.69 (95 percent confidence interval 0.60 to 0.79), P<0.001, I-squared = 0 percent. As sensitivity analyses, also including CABG-PATCH yields a summary hazard ratio of 0.73 (95 percent confidence interval 0.62 to 0.87 P<0.001, I-squared = 36 percent. Instead, including IRIS and DINAMIT yields a summary hazard ratio of 0.76 (95 percent confidence interval 0.65 to 0.91 P=0.002, I-squared = 44 percent. Including all 10 trials yields a summary hazard ratio of 0.80 (95 percent confidence interval 0.68 to 0.94 P=0.009, I-squared = 51 percent.

Table 8 ICD vs. no ICD: Number-needed-to-treat (95% confidence interval) to prevent one death, by study

Study | Year: | 1 | 2 | 3 | 4 | 5 | 6 | 7
MADIT, Moss 1996 8960472 | | 3.6 (2.2, 14) | 3.7 (2.4, 14) | 4.0 (2.7, 14) | 4.3 (2.9, 15) | 7.2 (5.0, 23)
COMPANION, Bristow 2004 15152059 | | 6.4 (3.8, 20) | 6.2 (3.9, 18) | 6.2 (4.0, 18)
MADIT II, Moss 2002 11907286 | | 9.7 (4.8, 58) | 7.6 (4.1, 41) | 7.4 (4.2, 38) | 7.5 (4.3, 37)
DEFINITE, Kadish 2004 15152060 | | 9.8 (3.7, inf) | 7.2 (3.2, inf) | 6.7 (3.1, inf) | 6.5 (3.1, inf) | 6.4 (3.2, inf)
SCD-HeFT, Bardy 2005 15659722 | | 11 (6.0, 77) | 12 (6.3, 85) | 11 (5.8, 71) | 10 (5.7, 68) | 10 (5.8, 67)
CAT, Bansch 2002 11914254 | | 17 (3.5, inf) | 12 (3.0, inf) | 8.6 (2.6, inf) | 8.4 (2.6, inf) | 8.2 (2.6, inf) | 8.0 (2.8, inf) | 8.1 (2.9, inf)
AMIOVIRT, Strickberger 2003 12767651 | | 29 (2.4, inf) | 26 (2.4, inf) | 25 (2.4, inf) | 22 (2.3, inf)

inf = infinite. See page 16 for study acronyms.

It should be noted that two studies—COMPANION95 and SCD-HeFT51—were three-arm studies that each included two non-ICD interventions that could be construed as the comparator of interest. The first study, COMPANION had the following three arms: ICD with CRT (CRT-D), CRT without ICD (CRT-P), and medical therapy. We determined that the medical therapy arm, not the CRT-P arm, was most similar to the comparison arms in other studies. The second study, SCD-HeFT included the following three arms: ICD, medical therapy (not including amiodarone), and medical therapy with amiodarone. The study found no difference in death rates between the amiodarone and no amiodarone groups. We chose the medical therapy without amiodarone as the most relevant control arm.

In sensitivity analyses, including the studies that were the most clinically different from the rest resulted in weaker effect sizes and greater statistical heterogeneity. Including the two studies that included patients with recent MIs (IRIS and DINAMIT) yielded a smaller effect favoring ICD but with statistical heterogeneity (HR 0.76 [95% CI 0.65, 0.91; I^2^ = 44%]). Alternatively, including CABG-Patch, which included patients undergoing CABG, yielded a similar effect (HR 0.73 [95% CI 0.62, 0.87; I^2^ = 36%]). Including all three atypical studies yielded the smallest effect with the greatest heterogeneity (HR 0.80 [95% CI 0.68, 0.94; I^2^ = 51%])

Figure 5 suggests that the reduction in overall mortality imparted by ICD is fairly stable over time from 1 to 7 years. The maximal difference in how many people have died was approximately 10 percent. The MADIT trial may differ from other trials in that the point estimates of the difference in cumulative death was about twice as large favoring ICD than other studies, but again the difference between ICD and no ICD was fairly stable, excluding year 5 when only 3 patients were still at risk of dying in the study (since most patients were not yet followed for that long). As suggested by the wide confidence intervals for HRs of all-cause mortality for MADIT and other trials (Figure 4), the difference between MADIT and the other studies may be due solely to random chance. The results in AMIOVIRT differed in that the benefit of ICD did not appear until year 3. The three atypical studies (CABG-Patch, DINAMIT, and IRIS; shown in grey in Figure 5), by definition consistent with their larger HRs for death compared with other studies, found no sustained benefit of ICD over time (the differences in cumulative death were near zero or positive, indicating fewer deaths with no ICD).

Figure 5 Differences in cumulative death proportions between ICD and no ICD, by year

ICD = implanted cardiac defibrillator, mo = months, y = years. See page 16 for study acronyms.

Data derived from digitized Kaplan-Meier curves. The mean difference curve is a rough average, weighted by number at risk or its imputed estimate, of studies excluding CABG-Patch, DINAMIT, and IRIS.

Figure 5 is a line graph with markers displaying the difference in cumulative death proportions between ICD and no ICD by year since randomization. The graph runs from 1 to 7 years. Each trial is graphed for the duration of time corresponding to the duration included in their Kaplan Meier curves. All trials display a fairly stable difference in cumulative death proportions over time within a range of about 0.1 (10 percent). With the exception of MADIT, the other 6 “typical” trials (AMIOVIRT, CAT, COMPANION, DEFINITE, MADIT II, and SCD-HeFT) show differences ranging from about -0.08 (favoring ICD) to +0.05 (favoring no ICD) at 1 year and differences ranging from about -0.12 to +0.02 for subsequent years. CAT favors no ICD at 1 and 2 years, AMIOVIRT favors no ICD at 4 years. Otherwise all typical trials favor ICD across time points. The MADIT trial shows a similar pattern as the other typical trials except that the range of differences across 1 to 4 years is about -0.18 to -0.25; the difference at year 5 is -0.43 but there were only 3 patients still at risk. A rough average of the difference across the typical trials, weighted by the number at risk at each time point is fairly stable about -0.05 to -0.07 across years 1 to 7. The three atypical trials (CABG-Patch, DINAMIT, and IRIS) all show difference lines that trend positive (favoring no ICD) from about 2 years onward.

The four nRCSs all examined the effects of ICD versus no ICD on all-cause mortality (Appendix Table 3). There was one prospective cohort study and three retrospective cohort studies. The studies varied in duration of followup from 2 to 5 years. All four provided data on all-cause mortality at 2 to 3 years. All found reduced all-cause mortality with ICD implantation versus no ICD. The range of adjusted HRs was 0.46 (95% CI 0.22, 0.98) to 0.78 (95% CI 0.44, 1.30), favoring ICD use. Three of the four studies found the adjusted HRs to be statistically significant.

Two of the trials (MADIT and CABG-Patch) also reported 30-day mortality data (Appendix Table 6). MADIT had no deaths in either group at 30 days. CABG-Patch did not report mortality rates, but noted no significant difference in 30-day mortality rates.

#### Subgroup Data: All-Cause Mortality

Eight RCTs and two nRCSs (17 publications) provided data on the differential effects of ICD placement (versus no ICD) based on 11 different subgroups.94 Table 5 presents subgroup data for subgroup variable pairs that were reported by at least two studies, including by sex, age, NYHA Class, LVEF, presence of heart failure, presence of left bundle branch block, QRS duration, time since myocardial infarction, blood urea nitrogen, and diagnosis of diabetes. Appendix Table 5 is a more complete version of the table, also including subgroup analyses that were reported by unique studies; this table also includes data based on type of heart disease (ischemic versus nonischemic), prior coronary revascularization, time since coronary revascularization, kidney function, and other specific subgroups not included in Table 5.

Table 5 Subgroup analysis data and meta-analyses of ICD vs. no ICD for all-cause death

Study, Author, Year, PMID | Subgroup 1 vs. 2 | OR^*^ (CI), Subgroup 1 | OR^*^ (CI), Subgroup 2 | ROR^†^ (CI) | Reported P^‡^
Sex
COMPANION, Bristow, 2004, 15152059 | Female vs. Male | 0.6 (0.3, 1.1) | 0.65 (0.4, 0.9) | 0.92 (0.43, 1.99) | nd
DEFINITE, Kadish, 2004, 15152060 | Female vs. Male | 1.1 (0.5, 2.6) | 0.49 (0.27, 0.90) | 2.24 (0.81, 6.23) | NS
DINAMIT, Hohnloser, 2004, 15590950 | Female vs. Male | 1.0 (0.5, 2.1) | 1.1 (0.7, 1.7) | 0.91 (0.39, 2.11) | 0.82
Hernandez^§^, 2010, 20009044 | Female vs. Male | 0.58 (0.41, 0.83) | 0.80 (0.63, 1.01) | 0.73 (0.47, 1.11) | 0.31
IRIS, Steinbeck, 2009, 19812399 | Female vs. Male | 1.0 (0.6, 1.7) | 1.1 (0.8, 1.5) | 0.91 (0.49, 1.67) | 0.15
MADIT II, Moss, 2002, 11907286 | Female vs. Male | 0.6 (0.3, 1.1) | 0.7 (0.5, 0.9) | 0.86 (0.42, 1.75) | 0.85
SCD-HeFT, Russo, 2008 18373605 | Female vs. Male | 0.90 (0.56, 1.43) | 0.71 (0.57, 0.88) | 1.27 (0.76, 2.12) | 0.54∥
CABG-Patch, Bigger, 1997, 9371853 | Female vs. Male | nd | nd | nd | NS
MADIT, Moss, 1996, 8960472 | Female vs. Male | nd | nd | nd | >0.2
Meta-analysis: | I^2^ =0% | | | 0.95 (0.75,1.20)
Age
Chan, 2009, 20031808 | <65 vs. 65-74 y | 0.74 (0.43, 1.28) | 0.76 (0.45, 1.29) | 0.97 (0.46, 2.08) | 0.43^¶^
COMPANION, Bristow, 2004, 15152059 | ≤65 vs. >65 y | 0.6 (0.3, 0.95) | 0.7 (0.5, 1.0) | 0.86 (0.44, 1.68) | nd
DEFINITE, Kadish, 2004, 15152060 | <65 vs. 65-84 y | 0.7 (0.3, 1.4) | 0.6 (0.3, 1.2) | 1.17 (0.41, 3.29) | NS
DINAMIT, Hohnloser, 2004, 15590950 | <60 vs. 60-80 y | 0.9 (0.4, 1.9) | 1.2 (0.8, 1.9) | 0.75 (0.31, 1.83) | 0.46
IRIS, Steinbeck, 2009, 19812399 | <65 vs. 65-80 y | 0.95 (0.6, 1.5) | 1.05 (0.8, 1.5) | 0.90 (0.52, 1.58) | 0.73
MADIT II, Moss, 2002, 11907286 | <60 vs. 60-69 y | 0.5 (0.2, 0.9) | 0.8 (0.5, 1.3) | 0.63 (0.26, 1.52) | NS^**^
SCD-HeFT, Bardy 2005 15659722 | <65 vs. ≥65 y | 0.68 (0.52, 0.95) | 0.86 (0.65, 1.14) | 0.79 (0.55, 1.13) | nd
Meta-analysis: | I^2^ =0% | | | 0.83 (0.66, 1.05)
Chan, 2009, 20031808 | 65-74 vs. ≥75 y | 0.76 (0.45, 1.29) | 0.59 (0.39, 0.90) | 1.29 (0.66, 2.52) | 0.43
Hernandez^§^, 2010, 20009044 | 65-74 vs. 75-84 y | 0.65 (0.47, 0.89) | 0.80 (0.62, 1.03) | 0.81 (0.54, 1.22) | 0.31
MADIT II, Moss, 2002, 11907286 | 60-69 vs. ≥70 y | 0.8 (0.5, 1.3) | 0.6 (0.45, 0.95) | 1.33 (0.73, 2.45) | NS^**^
Meta-analysis: | I^2^=17% | | | 1.03 (0.73, 1.45)
MADIT, Moss, 1996, 8960472 | Age, continuous | -- | -- | nd | >0.2
CABG-Patch, Bigger, 1997, 9371853 | Age, continuous | -- | -- | nd | NS
NYHA Class
DEFINITE, Kadish, 2004, 15152060 | NYHA Class II vs. III | 1.0 (0.5, 2.2) | 0.37 (0.15, 0.90) | 2.70 (0.85, 8.64) | NS^‡‡^
SCD-HeFT, Bardy 2005 15659722 | NYHA Class II vs. III | 0.54 (0.41, 0.81) | 1.16 (0.87, 1.44) | 0.47 (0.32, 0.67) | <0.001
Left ventricular ejection fraction
Chan, 2009, 20031808 | LVEF ≤25 vs. 26-35% | 0.73 (0.51, 1.04) | 0.59 (0.37, 0.93) | 1.24 (0.69, 2.22) | 0.61
DINAMIT, Hohnloser, 2004, 15590950 | LVEF <26 vs. 26-35% | 1.5 (0.8, 2.7) | 0.85 (0.5, 1.5) | 1.76 (0.78, 4.00) | 0.16
MADIT II, Moss, 2002, 11907286 | LVEF ≤25 vs. 25-30% | 0.6 (0.5, 0.9) | 0.7 (0.4, 1.2) | 0.86 (0.46, 1.60) | NS
Meta-analysis: | I^2^ =0% | | | 1.17 (0.80, 1.70)
COMPANION, Bristow, 2004, 15152059 | LVEF ≤20 vs. 20-35% | 0.6 (0.4, 0.9) | 0.7 (0.4, 1.1) | 0.86 (0.45, 1.64) | nd
DEFINITE, Kadish, 2004, 15152060 | LVEF <20 vs. 20-36% | 0.9 (0.4, 2.0) | 0.5 (0.3, 0.95) | 1.80 (0.67, 4.84) | NS
Heart failure
CABG-Patch, Bigger, 1997, 9371853 | Heart failure vs. No heart failure | nd | nd | nd | NS
Chan, 2009, 20031808 | Heart failure vs. No heart failure | 0.69 (0.50, 0.93) | 0.70 (0.35, 1.41) | 0.99 (0.46, 2.11) | 0.59
MADIT, Moss, 1996, 8960472 | Heart failure vs. No heart failure | nd | nd | nd | >0.2
IRIS, Steinbeck, 2009, 19812399 | Heart failure vs. No heart failure | 1.0 (0.7, 1.4) | 1.2 (0.8, 1.8) | 0.83 (0.49, 1.42) | 0.56
Left Bundle Branch Block
COMPANION, Bristow, 2004, 15152059 | LBBB vs. No LBBB | 0.5 (0.4, 0.8) | 0.9 (0.5, 1.6) | 0.56 (0.28, 1.09) | nd
MADIT, Moss, 1996, 8960472 | LBBB vs. No LBBB | nd | nd | nd | >0.2
MADIT II, Moss, 2002, 11907286 | LBBB vs. No LBBB | nd | nd | nd | NS
QRS duration
DEFINITE, Kadish, 2004, 15152060 | QRS <120 vs. ≥120 msec | 0.75 (0.4, 1.5) | 0.5 (0.2, 1.1) | 1.50 (0.51, 4.41) | NS
DINAMIT, Hohnloser, 2004, 15590950 | QRS <120 vs. ≥120 msec | 0.85 (0.5, 1.4) | 1.5 (0.8, 2.9) | 0.57 (0.25, 1.29) | 0.13
MADIT II, Moss, 2002, 11907286 | QRS <120 vs. 120-150 msec | 0.7 (0.5, 1.2) | 0.6 (0.4, 1.1) | 1.17 (0.60, 2.28) | NS^††^
SCD-HeFT, Bardy 2005 15659722 | QRS <120 vs. ≥120 msec | 0.84 (0.64, 1.11) | 0.67 (0.51, 0.95) | 1.25 (0.88, 1.79) | nd
Meta-analysis: | I^2^ =0% | | | 1.13 (0.82, 1.54)
Time since Myocardial Infarction
MADIT II, Wilber, 2004, 14993128 | Time since MI <18 vs. 18-51 mo | 0.97 (0.51, 1.81) | 0.52 (0.26, 1.05) | 1.87 (0.73, 4.79) | NS
SCD-HeFT, Piccini, 2011, 21109025 | Time since MI <18 vs. 18-59 mo | 0.7 (0.37, 1.31) | 0.54 (0.3, 0.98) | 1.30 (0.55, 3.08) | 0.33∥∥
MADIT II, Wilber, 2004, 14993128 | Time since MI 18-59 vs. 60-119 mo | 0.52 (0.26, 1.05) | 0.50 (0.26, 0.91) | 1.04 (0.41, 2.66) | nd
SCD-HeFT, Piccini, 2011, 21109025 | Time since MI 18-51 vs. 52-111 mo | 0.54 (0.3, 0.98) | 1.47 (0.75, 2.87) | 0.37 (0.15, 0.90) | 0.33∥∥
MADIT, Moss, 1996, 8960472 | Time since MI <6 vs. ≥6 mo | nd | nd | nd | >0.2
MADIT II, Moss, 2002, 11907286 | Time since MI <6 vs. ≥6 mo | nd | nd | nd | NS
Blood Urea Nitrogen
MADIT, Moss, 1996, 8960472 | BUN ≤25 vs. >25 mg/dL | nd | nd | nd | >0.2
MADIT II Moss, 2002, 11907286 | BUN ≤25 vs. >25 mg/dL | nd | nd | nd | NS
Diabetes mellitus
Chan, 2009, 20031808 | DM vs. No DM | 0.68 (0.45, 1.03) | 0.69 (0.48, 1.01) | 0.99 (0.56, 1.72) | 0.95
DINAMIT, Hohnloser, 2004, 15590950 | DM vs. No DM | 0.9 (0.5, 1.5) | 1.2 (0.8, 2.0) | 0.75 (0.37, 1.53) | 0.38
SCD-HeFT, Bardy 2005 15659722 | DM vs. No DM | 0.95 (0.71, 1.24) | 0.67 (0.52, 0.93) | 1.42 (0.99, 2.03) | nd
CABG-Patch, Bigger, 1997, 9371853 | DM vs. No DM | nd | nd | nd | NS
IRIS, Steinbeck, 2009, 19812399 | DM vs. No DM | nd | nd | nd | NS
MADIT II, Moss, 2002, 11907286 | DM vs. No DM | nd | nd | nd | NS
Meta-analysis: | I^2^=32% | | | 1.12 (0.78, 1.61)

The table includes only subgroup comparisons for which at least 2 trials reported analyses for similar subgroups. Meta-analyses were performed only if there were at least 3 such studies with sufficient data for a given subgroup comparison.

BUN = blood urea nitrogen, CI = 95% confidence interval, DM = diabetes mellitus, LBBB = left bundle branch block, LVEF = left ventricular ejection fraction, MI = myocardial infarction, nd = no data reported, NS = nonsignificant, NYHA = New York Heart Association, OR = odds ratio, PMID = PubMed ID, ROR = relative odds ratio. See page 16 for study acronyms.

* Reported odds ratio or relative risk or hazard ratio.

† Relative odds ratios and their confidence intervals calculated from reported odds ratios (etc.) for each subgroup.

‡ The reported P value for the interaction among subgroups.

§ OPTIMIZE-HF and GWTG-H

∥ For analysis of ICD vs. amiodarone vs. placebo.

¶ For analysis of <65 y vs. 65-74 y vs. ≥75 y.

** For analysis of <60 y vs. 60-69 y vs. ≥70 y

†† For analysis of <120 msec vs. 120-150 msec vs. ≥150 msec.

‡‡ For analysis of NYHA Class I vs. Class II vs. Class III.

∥∥ For analysis of <18 mo vs. 18-51 mo vs. 52-111 mo vs. >111 mo.

Among 76 subgroup analyses across the 10 studies, no significant differences were found in relative all-cause mortality between ICD and no ICD groups for subgroup analyses, with the exception of a comparison of NYHA Class II and III patients in SCD-HeFT (ICD effective in patients with Class II heart failure, but not Class III).51 Meta-analyses the relative OR of death for women vs. men (Figure 6), age subgroups (Figure 7), LVEF subgroups, QRS duration subgroups, and diabetes vs. no diabetes were all statistically homogeneous and found no significant difference between the respective subgroups.

Figure 6 Random effects model meta-analysis of relative odds ratio of ICD vs. no ICD for arrhythmic death between women and men

OR = odds ratio. See page 16 for study acronyms.

* Relative odds ratio or risk ratio or hazards ratio, as reported by studies.

† OPTIMIZE-HF and GWTG-H

Figure 6 is a forest plot that displays the meta-analyzed relative odds ratio of ICD versus no ICD for arrhythmic death between women and men. The relative odds ratio is the ratio of the odds ratio for women versus the odds ratio for men. There are 7 trials in the forest plot (COMPANION, DEFINITE, DINAMIT, combined OPTIMIZE-HF and GWTG-H, IRIS, MADIT II, and SCD-HeFT). The relative odds ratios across studies range from 0.72 (favoring women) to 2.25 (favoring men), but are mostly less than 1. The summary relative odds ratio is 0.95 (95 percent confidence interval 0.75 to 1.20), I-squared = 0 percent.

Figure 7 Random effects model meta-analysis of relative odds ratio of ICD vs. no ICD for arrhythmic death between younger and older subgroups

OR = odds ratio. See page 16 for study acronyms.

* Relative odds ratio or risk ratio or hazards ratio, as reported by studies.

† OPTIMIZE-HF and GWTG-H

Figure 7 is a pair of forest plots that display the meta-analyzed relative odds ratio of ICD versus no ICD for arrhythmic death between younger and older subgroups. In the plots, the relative odds ratios are the ratio of the odds ratio for those less than 60 to 65 years old versus older cohorts and for comparisons of older cohorts (65 to 74 versus older or 60-69 versus older). The forest plot of 60 to 65 versus older has 7 trials (Chan, COMPANION, DEFINITE, DINAMIT, IRIS, MADIT II, and SCD-HeFT). The relative odds ratios across studies range from 0.63 (favoring younger patients) to 1.17, but are mostly less than 1. The summary relative odds ratio is 0.83 (95 percent confidence interval 0.66 to 1.05), I-squared = 0 percent. The forest plot of the comparison of older subgroups has 3 trials (combined OPTIMIZE-HF adn GWTG-H, Chan, and MADIT II). The relative odds ratios across studies are 0.81 (favoring younger patients), 1.29, and 1.33. The summary relative odds ratio is 1.03 (95 percent confidence interval 0.73 to 1.45), I-squared = 17 percent.

SCD-HeFT51 and COMPANION95 examined time since coronary revascularization and both found greater, but not significantly different, benefits for ICD use in patients with more distant coronary revascularization. In MADIT II, among patients with revascularization >6 months prior HR=0.64 compared with HR=1.19 with more recent revascularization, but P=0.29.^97^ SCD-HeFT found that for patients with CABG >2 years prior HR=0.71 compared with HR=1.40 with more recent CABG (P=0.09), but time since percutaneous coronary revascularization was not associated with ICD benefit.109 An indirect comparison of ISIS and DINAMIT (which included patients with recent MIs, within 31 or 40 days) versus the remaining trials, suggests that patients with recent MIs may have no reduction in all-cause mortality (HR 1.05 [95% CI 0.86, 1.30]) than patients with more distant or no prior MIs (HR 0.69 [95% CI 0.60, 0.79]). By meta-regression, the difference between IRIS and DINAMIT and the other seven RCTs is statistically significant (P = 0.012).

Evaluation across studies for other indirect comparisons of subgroups did not reveal any additional subgroup differences.

#### Summary: All-Cause Mortality

Ten RCTs of fair to good quality and four nRCSs that directly compared ICD with no ICD (or amiodarone) provided consistent and precise findings of a significant benefit of ICD to reduce all-cause mortality (Table 7). There is a high strength of evidence that ICD use as primary prevention for patients who meet the current CMS practice criteria (no recent MI, no concurrent coronary revascularization) reduces the risk of all-cause mortality by about 31 percent (95% CI 21, 40) percent over the course of 3 to 7 years after implantation (Table 3). The reduction in all-cause mortality appears fairly stable over time across studies. Across RCTs, the NNT to prevent one death ranged from 6.2 (95% CI 4.0, 18) to 22 (95% CI 2.3, infinite) at the longest durations of followup (3 to 7 years). Overall, within-study analyses failed to show statistically significant differences for all-cause mortality across subgroups; however there may be an indication that ICDs are more effective in patients with more distant coronary revascularization or MIs compared with recent surgery (within either 6 months or 2 years) or MI (within 31 or 40 days). There are no data for different characteristics of clinicians implanting ICDs or facilities where ICDs are implanted.

Table 7 ICD vs. no ICD for primary prevention of SCD: Strength of evidence domains

Outcome | Study Design: No. Studies (N) | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Other Issues | Finding and Strength of Evidence
All-cause mortality (≥1 y) | RCT: 10 (8,606) | Low RoB (6 good, 4 fair) | Direct | Consistent | Precise | Undetected | | High ICD reduces all-cause mortality in patients meeting current practice criteria (no recent MI, no concurrent coronary revascularization) HR = 0.69 (95% CI 0.60, 0.79)
All-cause mortality (≥1 y) | nRCS: 4 (5,949)^*^ | Not graded | Direct | Consistent | Precise | Undetected | | High ICD reduces all-cause mortality in patients meeting current practice criteria (no recent MI, no concurrent coronary revascularization) HR = 0.69 (95% CI 0.60, 0.79)
All-cause mortality (30 d) | RCT: 2 (1096) | Low RoB (1 good, 1 fair) | Direct | Consistent | Imprecise | Undetected | 0 deaths in 1 applicable RCT | Insufficient Unknown difference in 30-day mortality
Sudden cardiac death (arrhythmic death) | RCT: 7 (4,093) | Low RoB (6 good, 1 fair) | Direct | Consistent | Precise | Undetected | | High ICD reduces SCD in patients meeting current practice criteria (no recent MI, no concurrent coronary revascularization) HR = 0.24 (95% CI 0.11, 0.56)
Sudden cardiac death (arrhythmic death) | nRCS: 2 (1,115)^*^ | Not graded | Direct | Consistent | Precise | Undetected | | High ICD reduces SCD in patients meeting current practice criteria (no recent MI, no concurrent coronary revascularization) HR = 0.24 (95% CI 0.11, 0.56)
Sustained ventricular tachyarrhythmia | 0 | | | | | | | Insufficient
Quality of life | RCT: 3 (1,825) | Low RoB (2 good, 1 fair) | Direct | Inconsistent | Imprecise | Undetected | | Low ICD may not affect quality of life
Other patient-reported outcomes | 0 | | | | | | | Insufficient

CI = confidence interval, HR = summary hazard ratio, ICD = implanted cardiac defibrillator, nRCS = nonrandomized comparative study, RoB = risk of bias, RCT = randomized controlled trial, SCD = sudden cardiac death.

* The nRCSs are not included in the determination of the strength of evidence

### Sudden Cardiac Death (Arrhythmic Death)

Seven RCTs (six good quality, one fair quality) and two nRCSs reported data on SCD (or death from cardiac arrhythmia) (Appendix Table 7). We meta-analyzed the RCT data, as shown in Figure 7. The studies followed patients for between 2 and 6 years. In general, SCD event rates were low, such that in four of the six RCTs, three or fewer individuals had SCD in one or both study groups during study followup. In the CAT study,91 no SCD events occurred at 2 years of followup. Nevertheless, in all studies (except CAT), SCD was less common in patients who had an ICD than those without an ICD. The summary HR across the four primary analysis trials (excluding the atypical studies) was 0.37 (95% CI 0.26, 0.52) with no statistical heterogeneity (I^2^ = 0). However, the lack of heterogeneity can largely be ascribed to the wide CIs within each study. Sensitivity analysis including IRIS and DINAMIT yielded a smaller effect size (summary HR 0.241;95% CI 0.31, 0.54). Figure 9 suggests that the effect of ICD versus no ICD on SCD proportions over time is fairly stable but may increase beyond 2 or 3 years. Among the four eligible RCTs with adequate data (Table 9), the estimated NNT to prevent one arrhythmic death was 1.9 to 3.2 in three trials (approximate 95% CIs 1.3, 16) and 11 (95% CI 1.3, infinite) in the fourth RCT.

Figure 8 Random effects model meta-analysis of ICD vs. no ICD for arrhythmic death

∼ = approximately; CI = confidence interval; f/up = followup; HR = hazard ratio; ICD = implantable cardiac defibrillator; n/N = total events (deaths)/total analyzed. See page 16 for study acronyms.

* Hazard ratio and confidence interval estimated from reported data.

† Not included in meta-analyses (the alternative comparison for each study was the only comparison included in meta-analyses).

‡ Differential use of beta blockers between ICD and amiodarone groups (but not between ICD and no ICD groups).

Figure 8 is a forest plot that displays the meta-analyzed hazard ratio of arrhythmic death with confidence intervals for individual trials. There are 7 trials in the forest plot (CAT, AMIOVIRT, MADIT, DEFINITE, DINAMIT, IRIS, and SCD-HeFT). SCD-HeFT is included twice for comparisons of ICD versus no ICD and ICD verus amiodarone. The former comparison is included in the meta-analaysis The hazard ratios across studies range from 0.20 to 0.62; There were no events in CAT and thus no hazard ratio is calculated. The maximum duration of followup ranges from 2 to 6 years. The mean duration of followup ranges from about 2 to 3.8 years. Including only the 5 “typical” studies, the summary hazard ratio is 0.37 (95 percent confidence interval 0.26 to 0.52), P=0.001, I-squared = 0 percent. As sensitivity analyses, also including IRIS and DINAMIT yields a summary hazard ratio of 0.41 (95 percent confidence interval 0.31 to 0.54, P<0.001, I-squared = 0 percent.

Figure 9 Differences in cumulative sudden cardiac/arrhythmia death proportions between ICD and no ICD, by year

ICD = implanted cardiac defibrillator, mo = months, SCD = sudden cardiac death, y = years. See page 16 for study acronyms.

Data derived from digitized Kaplan-Meier curves, where available. AMIOVIRT, CAT, and MADIT did not report Kaplan Meier curves. CAT reported data for years 1 and 2.

AMIOVIRT and MADIT reported only total numbers of death; the points for these two studies are plotted at their approximate mean duration of followup.

Figure 9 is a line graph with markers displaying the difference in cumulative sudden cardiac death proportions between ICD and no ICD by year since randomization. The graph runs from 1 to 6 years. Each trial is graphed for the duration of time corresponding to the duration included in their Kaplan Meier curves or for the reported time points. CAT has no events (and thus no difference) at 1 and 2 years. AMIOVIRT found a difference of -0.02 (2 percent, favoring ICD) at years. MADIT found a difference of -0.10 at 2 years. DEFINITE found that the difference changed over time: -0.005 at 1 year, -0.05 at 2 years, -0.07 at 3 years, and -0.08 at both years 4 and 5. SCD-HeFT found that the difference increased over time: -0.03 at 1 year, -0.05 at 2 and 3 years, -0.07 at 4 years, and -0.09 at 5 years. The atypical trial DINAMIT found a fairly stable difference over time, ranging from -0.04 to -0.05 at years 1 through 4. The atypical trial IRIS found a difference of -0.04 at year 1, -0.06 or -0.07 at years 2 to 5 and -0.09 at year 6.

Table 9 ICD vs. no ICD: Number-needed-to-treat (95% confidence interval) to prevent one tachyarrhythmia death, by study^*^

Study | Year: | 1 | 2 | 3 | 4 | 5
MADIT, Moss 1996 8960472 | | | 2.0 (1.4, 16)
DEFINITE, Kadish 2004 15152060 | | 2.6 (1.3, 36) | 2.0 (1.3, 13) | 1.9 (1.3, 12) | 1.9 (1.3, 11) | 1.9 (1.3, 11)
AMIOVIRT, Strickberger 2003 12767651 | | | 11 (1.3, inf)
SCD-HeFT, Bardy 2005 15659722 | | 4.2 (2.6, 9.1) | 3.5 (2.3, 6.9) | 3.4 (2.3, 6.4) | 3.2 (2.3, 6.0) | 3.2 (2.2, 5.8)

inf = infinite. See page 16 for study acronyms.

* There were no tachyarrhythmia deaths in CAT by 2 years, therefore this study is not included.

The two nRCSs examined the effects of ICD versus no ICD on SCD (Appendix Table 7). Fonarow 2000,^106^ a retrospective cohort study, followed patients for 2 years; Chan 2009,^105^ a prospective cohort study, followed patients for 3 years. Both found lower risk of SCD with ICD implantation (0 vs. 22% actuarial rate over 2 years, P = 0.05; and adjusted HR = 0.65, 95% CI 0.40, 1.03 over 3 years).

#### Subgroup Data: Sudden Cardiac Death

Subgroup analyses of SCD-HeFT related to time since MI, prior coronary revascularization, and time since revascularization and subgroup analyses of MADIT II related to time since coronary revascularization and presence of kidney disease all failed to find a significant interaction between ICD placement and subgroups (Table 6).96,97,109,110 No other subgroup analyses have been reported. Indirect comparison across studies fails to show any differences based on patient or other characteristics. There are no data for different characteristics of clinicians implanting ICDs or facilities where ICDs are implanted.

Table 6 Subgroup analyses of ICD vs. no ICD for sudden cardiac death

Study, Author, Year, PMID | Subgroups HR/RR (95% CI) | | | | P Interaction
SCD-HeFT, Piccini, 2011, 21109025 | Time Since MI | | | | P=0.68
SCD-HeFT, Piccini, 2011, 21109025 | <18 mo: | 0.47 (0.16, 1.42) | 18-51 mo: | 0.28 (0.073, 1.10) | P=0.68
SCD-HeFT, Piccini, 2011, 21109025 | 52-111 mo: | 0.24 (0.063, 0.89) | >111 mo: | 0.25 (0.065, 0.97) | P=0.68
SCD-HeFT, Al-Khatib 2008, 18479330 | Prior CABG: | 0.52 (0.26, 1.02) | No CABG: | 0.44 (0.23, 0.83) | P=0.94
SCD-HeFT, Al-Khatib 2008, 18479330
SCD-HeFT, Al-Khatib 2008, 18479330 | Prior PCI: | 0.31 (0.08, 1.13) | No PCI: | 0.51 (0.31, 0.85) | P=0.53
SCD-HeFT, Al-Khatib 2008, 18479330
SCD-HeFT, Al-Khatib 2008, 18479330 | Time Since CABG: | nd | | | P=0.38
SCD-HeFT, Al-Khatib 2008, 18479330
SCD-HeFT, Al-Khatib 2008, 18479330 | Time Since PCI: | nd | | | P=0.80
MADIT II, Goldenberg, 2006, 16682305 | Time since CR
MADIT II, Goldenberg, 2006, 16682305 | ≤6 mo: | 2.01 (0.18, 22.22) | >6 mo: | 0.34 (0.19, 0.61) | P=0.16
MADIT II, Goldenberg, 2006, 16682305
MADIT II, Goldenberg, 2006, 16682305 | 7-60 mo: | 0.27 (0.11, 0.66) | >60 mo: | 0.40 (0.19, 0.86) | nd
MADIT II Goldenberg, 2006, 16893702 | Kidney Disease
MADIT II Goldenberg, 2006, 16893702 | eGFR<35: | 0.95 (0.23, 4.00) | eGFR ≥35: | 0.34 (0.20, 0.56) | P=0.19
MADIT II Goldenberg, 2006, 16893702
MADIT II Goldenberg, 2006, 16893702 | eGFR 35-59: | 0.37 (0.19, 0.74) | eGFR≥60: | 0.32 (0.15, 0.69) | nd

CABG = coronary artery bypass graft, CI =confidence interval, CR = coronary revascularization, eGFR = estimated glomerular filtration rate (in mL/min/m^2^), HR = hazard ratio, ICD = implantable cardiac defibrillator, MI = myocardial infarction, mo = month, nd =no data, PCI = percutaneous coronary revascularization, PMID = PubMed ID, Revasc = revascularization, RR = risk ratio. See page 16 for study acronyms

#### Summary: Sudden Cardiac Death

Seven RCTs of generally good quality and two nRCSs that directly compared ICD with no ICD (or amiodarone) provided consistent and sufficiently precise findings of a significant benefit of ICD to reduce SCD (Table 7). There is a high strength of evidence that ICD use as primary prevention for patients who meet the current CMS practice criteria (no recent MI, no concurrent coronary revascularization) reduces the risk of SCD by about 63 percent (95% CI 48, 74) over the course of 2 to 6 years after implantation (Table 3). There is a suggestion across studies that the effect of ICD on SCD over time may increase beyond 2 or 3 years. Across RCTs, the NNT to prevent one arrhythmic death ranged from about 2 to 3 (approximate 95% CI 1.3, 16) to 11 (95% CI 1.3, infinite). The evidence fails to support a difference in the benefit of ICD based on time since MI, coronary revascularization, or kidney disease. There is insufficient evidence to evaluate differential effects of ICD on SCD in other subgroups of patients or based on different characteristics of clinicians implanting ICDs or facilities where ICDs are implanted.

### Sustained Ventricular Tachyarrhythmia

No study that directly compared ICD to no ICD (or amiodarone) reported on long-term sustained ventricular tachyarrhythmia. The only study to report any data on sustained ventricular tachycardia was CABG-Patch,100 which reported event rates postoperatively as an adverse event of CABG surgery with or without ICD placement.

#### Summary: Sustained Ventricular Tachyarrhythmia

There is insufficient evidence to estimate the effect of ICD placement for primary prevention on the rate of sustained ventricular tachyarrhythmia episodes (Table 7).

### Quality of Life

Three RCTs (two of good quality, 1 fair) reported on the effect of ICD placement versus no ICD placement on various measures of QoL (Appendix Table 9). The three trials each evaluated different QoL measures, including the Health Utility Index 3 (MADIT II101, a health utility assessing health-related QoL across eight attributes: vision, hearing, speech, ambulation, dexterity, emotion, cognition, and pain and discomfort), the Quality of Well-being Schedule (AMIOVIRT103, assessing both functional and symptom status, translatable into quality-adjusted life years), the State Trait Anxiety Inventory (AMIOVIRT103, focusing on the anxiety component of QoL), the Short Form 36 (SF-36) (CABG-Patch100, evaluating eight health concepts: physical functioning, role limitations due to physical problems, bodily pain, general health perceptions, vitality, social functioning, role limitations due to emotional problems, mental health, health transition (perceived change in health), and the Perception of Health Transition scale (CABG-Patch100, where patients assess their current health status relative to 1 year before). No QoL scale was used by more than a single study.

MADIT II101 and AMIOVIRT103 found no statistically significant difference in QoL between ICD and control arms according to the Health Utility Index 3, the State Trait Anxiety Inventory, and the Quality of Well-being Schedule. CABG-Patch,100 which compared CABG plus ICD placement with CABG without ICD, reported on seven of the SF-36 subscales (not vitality) along with the Perception of Health Transition scale. The trial found no significant difference between the two groups for five of the seven evaluated SF-36 QoL domains, but control patients (those without ICD) reported significantly better QoL for the subscales regarding emotional role functioning and mental health. In addition, control patients had better perception of health transition compared with 1 year prior.

#### Subgroup Data: Quality of Life

No study reported subgroup analyses for the relative effect of ICD versus no ICD on QoL.

#### Summary: Quality of Life

Across three RCTs of good and fair quality, only one found that some measures of QoL favored no ICD over ICD (Table 7). While the three trials covered a broad range of QoL measures, no specific QoL measure was evaluated by more than a single trial. Furthermore, the single trial that did find a difference (favoring no ICD) for some measures of QoL, is of limited applicability to current practice, both because all patients had CABG and because the trial implanted epicardial ICD systems which are much more invasive and large compared to the transvenous ICDs currently employed. It is unknown to what degree the concurrent CABG or the older technologies may have led to the worse emotional role, mental health, and perception of overall health in those who received ICDs.

Given the sparseness of data on QoL and the lack of consistency across trials, overall, there is a low strength of evidence low strength of evidence that failed to show a consistent effect of ICD placement on QoL (Table 3). There is insufficient evidence to evaluate differential effects of ICD on QoL in different populations of patients or based on different characteristics of facilities where ICDs are implanted.

### Other Patient-Reported Outcomes

No eligible study reported other patient-reported outcomes of interest. Therefore, there is insufficient evidence to estimate the effect of ICD placement for primary prevention on other patient-reported outcomes (Table 7).

## Key Questions 1b & 1c In Candidates for ICD Implantation for Primary Prevention of SCD, What Are the Effects of ICD with ATP versus ICD alone, or of ICD with CRT versus ICD alone on Clinical Outcomes and Patient-Reported Outcomes? How Do Outcomes Vary Within Subgroups?

We searched for studies that examined the effect of ATP added to ICD, or the effect of CRT added to ICD, versus ICD alone. We did not include comparisons of shock algorithms or algorithms pertaining to pacing for bradycardia, different manufacturers of equivalent ICDs, or different numbers of leads used per se (except as required for CRT). The findings and strength of evidence for outcomes with sufficient evidence for the comparison of CRT-D versus ICD are summarized in Table 8.

No study examined the effect of adding ATP in patients undergoing ICD implantation for predominantly primary prevention. Four studies that met eligibility criteria directly compared ICD with CRT versus ICD alone (Table 10).73,111,112 All focused on congestive heart failure outcomes, which were not outcomes of interest for this review. We did not meta-analyze the studies since there were only two sufficiently large studies to analyze death and meta-analysis would not provide a better estimate of the effect size than evaluating the two large trials separately.

Table 10 Summary of findings for CRT-D vs. ICD

Outcome | Study Design: No. Studies (N) | Findings | Strength of Evidence
All-cause mortality | CRT-D vs. ICD RCT: 4 (3,743) | - The 2 larger trials found either no difference (HR = 1.00) or a significant benefit with CRT-D (HR = 0.75). No differences in effect were found between patients with ischemic or nonischemic heart disease or with NYHA Class II or III cardiomyopathy; - There was no evidence regarding the comparison of CRT-D and ICD in subgroups of patients or based on different characteristics of facilities where ICDs are implanted. | Insufficient

[underlined: Abbreviations]: CI = confidence interval, CRT-D = cardiac resynchronization therapy-defibrillator, HR = hazard ratio, ICD = implantable cardioverter–defibrillator, No. = number, NYHA = New York Heart Association, RCT = randomized, controlled trial

### Studies

#### MADIT-CRT

MADIT-CRT73 compared the combination of CRT plus ICD (CRT-D) with ICD alone in patients with ischemic or nonischemic cardiomyopathy, an LVEF <30 percent, and QRS duration >130 ms. We assessed the study to be of good quality. Patients' mean age was 64 years and three-quarters of them were men. Their mean LVEF was 24 percent. About 15 percent of patients had NYHA Class I ischemic heart disease, 40 percent had Class II ischemic heart disease, and 45 percent had Class II nonischemic heart disease. This distribution reflects the study's eligibility criteria. About 65 percent had a QRS duration≥150 ms. About 30 percent had diabetes.

After 5 years of followup, 74 of 1089 patients (6.8%) who received CRT-D died and 53 of 731 (7.3%) patients with ICD only died. The HR for all-cause death with CRT-D versus ICD only was 1.00 (95% CI 0.69, 1.44). The effects of adding CRT in either patients with ischemic or with nonischemic cardiomyopathy were similar and not statistically significantly different between populations. For patients with ischemic heart disease (NYHA Class I or II), the HR was 1.06 (95% CI 0.68, 1.64); for patients with nonischemic heart disease (NYHA Class II only), the HR was 0.87 (95% CI 0.44, 1.70). MADIT-CRT did not evaluate other outcomes of interest to this review or other subgroups of interest for all-cause mortality.

In a comparison of patients who had and who did not have coronary revascularization prior ICD placement,113 the frequency of combined ventricular tachyarrhythmia or death did not differ among patients with CRT-D or ICD, regardless of coronary revascularization history or time since coronary revascularization.

#### RAFT

RAFT compared CRT-D with ICD alone in patients with NYHA Class II or III heart failure, LVEF≤30 percent, QRS duration ≥200 msec, sinus rhythm or controlled atrial fibrillation, and planned ICD implantation.74 The study was not restricted to patients receiving ICDs for primary prevention, but only 14 percent had a history of a prior SCD episode. We assessed the study to be of good quality. Patients' mean age was 66 years and 83 percent were men. Their mean LVEF was 23 percent and 80 percent had NYHA Class II heart failure; the remainder had Class III heart failure. Their mean QRS duration was 158 ms. About one-third had diabetes.

During a total of 6 years of followup (mean 40 months), 236 of 904 (26%) patients who had received ICD alone died and 186 of 894 (21%) with CRT-D died; thus the HR for all-cause death was 0.75 (95% CI 0.64, 0.87), favoring CRT-D. No difference in effect size was found for patients with Class II or Class II heart failure. The HR for all-cause death among those with Class II heart failure was 0.71 (0.56, 0.91) and for those with Class III heart failure 0.79 (0.58, 1.08).

#### Diab 2011

In the only RCT of ICD for primary prevention without an acronym name, Diab 2011 compared CRT-D with ICD alone in patients with NYHA Class III or IV heart failure, LVEF <35 percent, and QRS duration ≥120 ms, but with echocardiographic evidence of no mechanical dyssynchrony.112 We assessed the study to be of good quality, although underpowered for clinical outcomes. Patients' mean age was 66 years and 89 percent were men. Their mean LVEF was 26 percent. Almost 90 percent had NYHA Class III heart failure. Their mean QRS duration was 138 ms. The percentage of patients with diabetes was not reported.

After 6 months of followup, 2 of 22 (9%) patients who received ICD alone died, but none of 24 patients with CRT-D died. One patient in each group was hospitalized for surgical lead implantation or repositioning. No other outcomes of interest and no subgroup analyses were reported.

#### MENDMI

MENDMI compared CRT-D with ICD alone in patients with a recent MI (within 3 to 16 days), LVEF ≤35 percent, and a wall motion abnormality on echocardiogram in >5 of 16 cardiac segments.111 Based on their recent MIs, current guidelines would not recommend ICD in these patients. We assessed the study to be of fair quality, having differential attrition rates. It was also underpowered for clinical outcomes. Patients' mean age was 57 years and 75 percent were men. Their mean LVEF was 28 percent. About two-thirds had NYHA Class II or III heart failure. Their mean QRS duration was 88 ms. Before a protocol revision, diabetes had been an exclusion criterion, so only 8 percent of patients had diabetes.

In the trial, 42 patients received CRT-D and 38 received ICD alone. Within 1 year of followup, one patient died in each arm. The only hospitalization postimplantation occurred after a failed ICD induction, but it was not reported which ICD the patient had.

### Summary

Four RCTs compared CRT-D with ICD alone, one of which included patients with very recent MIs (within 2 weeks) (Table 11). The two large trials had discordant findings, such that MADIT-CRT found no difference in death between CRT-D and ICD alone in patients with ischemic NYHA Class I cardiomyopathy or ischemic or nonischemic NYHA Class II cardiomyopathy, while RAFT found a statistically significant 25 percent reduction in death with CRT-D in patients with Class II or III ischemic or nonischemic cardiomyopathy. The other two RCTs were greatly underpowered for clinical outcomes and therefore adds little to the evidence base for outcomes of interest to this review. The evidence is insufficient to determine whether there is a difference in death between CRT and ICD alone for primary prevention or whether there may be a subpopulation of patients (captured by RAFT) who may benefit from CRT-D (Table 8). Both large trials found no difference in effect between either patients with ischemic or nonischemic heart disease or patients with Class II or III cardiomyopathy. There is insufficient evidence for all other outcomes and comparisons of interest, including differential effects of CRT-D and ICD on all-cause mortality for other populations of patients or different characteristics of facilities where ICDs are implanted; the effect of CRT-D versus ICD on SCD, sustained ventricular tachyarrhythmia, general QoL, or other general patient-reported outcomes. No study examined the effect of adding ATP in patients undergoing ICD implantation for predominantly primary prevention.

Table 11 ICD vs. CRT-D

Table 11 ICD vs. CRT-D: Study characteristics

Study Author Year PMID | Intervention (Control) | NYHA class | Ischemic | Non-ischemic | Non sustained VT | % LVEF | Total N | Primary outcome | Duration followup | ICD type/No. of leads | Enrollment period
Diab 2011 21700757 | ICD (CRT-D) | III, IV | Yes | Yes | nd | ≤35 | 73 | Peak oxygen consumption | 6 mo | nd | 2007-2009
MADIT-CRT Moss 2009 19723701 | ICD (CRT-D) | I, II | Yes | Yes | No | ≤30 | 1820 | All-cause death or nonfatal heart failure event | 4 y mean 2.4 y | Single-, dual-chamber vs. biventricular | 12/22/2004-4/23/2008
MENDMI Chung 2010 20852059 | ICD (CRT-D) | I, II, III | nd | Yes | NR | ≤35 | 80 | Change in LV end-diastolic volume at 12 mo | 12 mo | Single-, dual-chamber vs. biventricular | 2005-2008
RAFT Tang, 2010 21073365 | ICD (CRT-D) | II, III | Yes | Yes | nd | ≤30 | 1798^*^ | Death or hospitalization for heart failure | 40 mo mean 3.3 y | nd | 1/2003-2/2009

CRT-D = cardiac resynchronization therapy defibrillator, ICD = implantable cardiac defibrillator, LV = left ventricular, MADIT-CRT = Multicenter Automatic Defibrillator Implantation Trial with Cardiac Resynchronization Therapy, MENDMI = Prevention of Myocardial Enlargement and Dilation Post Myocardial Infarction Study, mo = month, nd = not documented, NYHA = New York Heart Association, VT = ventricular tachycardia, y = year

* 20% of patients had ICDs implanted for secondary prevention of sudden cardiac death.

Table 11 CRT-D vs. ICD for primary prevention of SCD: Strength of evidence domains

Outcome | Study Design: No. Studies (N) | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Other Issues | Finding and Strength of Evidence
All-cause mortality (≥1 y) | RCT: 4 (3,743) | Low RoB (3 good, 1 fair) | Direct | Inconsistent | Precise | Undetected | | Insufficient The 2 larger trials found either no difference (HR = 1.00) or a significant benefit with CRT-D (HR = 0.75) No differences in effect were found between patients with ischemic or nonischemic heart disease or with NYHA Class II or III cardiomyopathy
All-cause mortality (30 d) | 0 | | | | | | | Insufficient
Sudden cardiac death (arrhythmic death) | 0 | | | | | | | Insufficient
Sustained ventricular tachyarrhythmia | 0 | | | | | | | Insufficient
Quality of life | 0 | | | | | | | Insufficient
Other patient-reported outcomes | RCT: 1 (46) | Low RoB (1 good) | Direct | Consistent | Imprecise | Undetected | | Insufficient Unclear whether rates of hospitalization for surgical lead implantation or repositioning differ

CI = confidence interval, CRT-D = cardiac resynchronization therapy with defibrillator, HR = summary hazard ratio, ICD = implanted cardiac defibrillator, nRCS = nonrandomized comparative study, NYHA = New York Heart Association, RoB = risk of bias, RCT = randomized controlled trial.

## Key Question 2a What are the adverse events related to treatment with an ICD for primary prevention of SCD?

## Key Question 2b How do adverse events vary within subgroups?

Although this report is focused on primary prevention, for our review of adverse events, we also included studies of mixed populations of patients with ICDs for either primary or secondary prevention. This was done not only to enrich the evidence base but also because many adverse events are related to ICD placement rather than the indication for the device and thus are likely to be more similar than different across populations with primary and secondary indications.

We identified a total of 59 articles contributing data on adverse events, 14 with results for early adverse events, i.e. adverse events occurring during hospitalization for ICD implantation or up to 30 days after implantation, 33 studies contributing data for late adverse events and 22 studies on inappropriate shock. The findings and strength of evidence for adverse events related to ICD are summarized in Table 12.

Table 12 Summary of findings regarding adverse event

Outcome | Study Design: No. Studies (N) | Findings | Strength of Evidence
Early AEs (In-hospital) | RCT: 3 (3,867) Observational: 11 (356,515^*^) [overlapping cohorts] | During hospitalization, 2.8–3.6% of patients had any adverse event. Serious adverse events occurred in 1.2–1.35% after ICD placement. The most common specific adverse events were lead dislodgement (0.7–1.2%) and hematoma (0.8–1.1%). Other in-hospital adverse events occurred in ≤0.5% of patients receiving ICDs Based on within-study subgroups analyses, there may be higher rates of adverse events among patients receiving dual-chamber ICDs, CRT-D, among older patients, women, and those with ESRD. Physicians and hospitals with lower volume of implantation and operators other than electrophysiologists may have more adverse events. | High
Late AEs (Out of hospital) | RCT: 3 (2,149) Observational: 28 reports of 22 independent cohorts (99,725^†^) | Device-related adverse events occurred in <0.1–6.4% of ICD patients during 2–49 month followup. Other relatively common adverse events included lead malfunction (<0.1–3.9% during 1.5–40 month followup), infection (0.2–3.7% for 1.5–49 month followup), and thrombosis (0.2–2.9% for 1.5–49 month followup). Based on within-study subgroup analyses, there may be more lead-related adverse events in women. There was no apparent difference in adverse events between CRT-D and ICD or between dual and single chamber ICDs. | Low
Inappropriate shock | RCT: 1 (249) Observational: 21 reports of 17 independent cohorts (212,063^‡^) | Inappropriate shock occurred in 3–21% of patients during 1–5 year followup. Based on within-study subgroup analyses, there may be more inappropriate shocks among younger patients Evidence on the difference in inappropriate shocks between dual and single chamber ICDs was inconsistent. Limited data show no apparent difference in inappropriate shocks between CRT-D and ICD. | Moderate

[underlined: Abbreviations]: AE = adverse event, CRT-D = cardiac resynchronization therapy-defibrillator, ESRD = end stage renal disease, ICD = implantable cardioverter–defibrillator, No. =number, RCT = randomized, controlled trial

* Largest independent N

† Largest independent N. Two large cohorts: N=38,992 (PMID 21795298), N=15,387 (PMID 19925609).

‡ Largest independent N. One large cohort: N=185,778 (PMID 21098452)

Figure 10 and Appendix Table 11 shows the quality of reporting for harms across the comparative and cohort studies according to the questions shown in the legend. All reports from one database (i.e., the NCDR ICD Database and the EPD-Vision Database) were graded jointly. Most studies prespecified at least one adverse event in the Methods section, and many used a standardized or precise definition. It seemed that all prespecified harms were reported. Most studies reported the active collection of harms, although some did not comment on ascertainment. Very few studies explicitly stated whether passive (patient-initiated) ascertainment was used (as either the primary or supplementary mode of collection). Most studies described the timing of adverse event collection at regularly scheduled postimplantation visits. Our review only included studies providing the number of patients experiencing harms (numerator) and the total number at risk (denominator).

Figure 10 McHarms quality measures for 38 independent studies reporting adverse event data

The numbers within the bars represent the number of studies within each category.

Q1 Were any harms prespecified (a priori) in Methods section?
Q1a If yes, were any of them prespecified with a priori standardized or precise definitions?
Q2 Were all prespecified harms reported?
Q3 Was the mode of harms collection ACTIVE (sought to collect information on AEs)?
Q4 Was the mode of harms collection PASSIVE? (Participants are not specifically asked about or tested for the occurrence of adverse events. Rather, adverse events are identified based on patient reports made on their own initiative.)
Q5 Did the study specify the TIMING and/or FREQUENCY of collection of harms?
Q6 Is the number of participants who experience harms provided for each arm?
Q7 Is the number at risk for harms (denominator) provided for each arm?
Q8 For studies comparing adverse events across two or more arms: Is there a STATISTICAL analysis of relative harms between groups?

Figure 10 is a bar chart enumerating how many studies met criteria for the MacHarms quality measures. The specific MacHarms items are described in the figure legend. The figure displays the following: harms prespecified yes 31, no 7; prespecified harms had standard definitions yes 27, no 4, not applicable 5; all prespecified harms reported yes 31, not applicable 5; active collection yes 26, no data 12; passive collection yes 2, no data 36; timing and frequency yes 27, no 11; numerator yes 37, no 1; denominator yes all 38; statistical analysis yes 6, no 2, not applicable 30.

Overall, our screening and selection criteria enriched the database for studies with purposeful reporting of adverse events. The strength of evidence for early (in-hospital) adverse events is high as they are derived from a registry with standard definitions, wide capture, and a large number of patients. The strength of evidence for late adverse events is low because there are only a few studies for each outcome and outcome definitions and ascertainment varied. The strength of evidence for inappropriate shocks was moderate with good data ascertainment but imprecise rates across studies.

### Early Adverse Events from the NCDR ICD Registry

We identified 11 studies reporting harms ascertained in the NCDR ICD registry (Appendix Table 12).62,66,67,114-121 These studies ranged in size from 44,805 to 356,515 patients; the patients overlapped to a large degree across studies; therefore the patient populations are not independent. The percentage of patients receiving an ICD for primary prevention in the individual studies ranged from 68 to 100 percent (with one study not reporting the proportion). Although the NCDR ICD registry is a comprehensive database with purposeful data collection, it is restricted to the data capture during the hospitalization for ICD implantation and may not capture all early adverse events.

Appendix Table 13 shows the range of rates for each adverse event category across the 10 reports reporting rates.62,66,67,114-118,120,121 One additional study provided subgroup data only.119 Table 13 presents a summary of the early adverse event rates across studies. The percentage of patients with any adverse events ranged from 2.77 to 3.55 percent across cohorts. Wei 2011^121^ reported a substantially higher adverse event percentage (4.6%) than other studies, so we did not include it in the range. The higher rates of adverse events in Wei 2011 most likely occurred because the study involved patients who were at higher risk; namely, it included patients who had a B-type natriuretic peptide value at baseline, a laboratory test that which is tested in patients evaluated for heart failure. This study also did not focus on patients with a first ICD.

The most commonly reported specific early adverse events were lead dislodgement (0.73-1.2% of patients) and hematoma (0.84-1.1% of patients). All other specific adverse events occurred in less than 0.51 percent of patients.

#### Subgroup Analyses

All 11 studies using the NCDR ICD database reported subgroup analyses (Appendix Table 14). Statistical tests were not always provided for comparison of adverse event rates in subgroups, but 7 of the 11 studies reported statistical comparisons for at least one subgroup.

The rate of any adverse events was consistently and significantly higher in groups with dual-chamber ICDs and CRT-Ds (vs. single-chamber), older age, female sex, end-stage renal disease (ESRD), and implantation either by physicians or at hospitals with a low volume of implantations performed. The findings from analyses for specific adverse events were consistent with these subgroup effects or were not statistically significant. The only exception is a study showing a lower, rather than higher, risk of coronary venous dissection in patients with ESRD,114 but the overall rate of this complication was low at 0.15 percent.

Other results of subgroup analyses were variable. Findings from two analyses (Tsai 2011 and Cheng 2010) for race and ethnicity were inconsistent.62,120 Results for diabetes were non-significant in two studies. Haines 2011^117^ found no statistically significant difference in the risk of an adverse event or death in patients who had received an ICD for primary prevention versus those who received an ICD for secondary prevention.

Four studies used the NCDR database to ascertain the rates of adverse events according to physician training.62,66,67,120 In general, electrophysiologists had the lowest (or among the lowest) rates of adverse events. Tsai 2011^120^ found a statistically higher odds ratio (OR) for any adverse event or death associated with surgeons (OR 1.49, P<0.001), nonelectrophysiologist cardiologists (OR 1.20, P<0.001), or other specialists (OR 1.18, P<0.05) rather than board-certified electrophysiologists. Cheng 2010^62^ reported a higher risk of lead dislodgement in association with physicians trained under alternative pathways (HR 1.23; 95% CI 1.07, 1.45), and a trend for surgery board–certified physicians (HR 1.22; 95% CI 0.95, 1.56) as compared with electrophysiologists. Freeman 2012^67^ reported the lowest rates of any adverse event for electrophysiologists but did not report statistical comparisons among physician groups. Finally, Curtis 2009^66^ compared the rates of adverse events across electrophysiologists, nonelectrophysiologist cardiologists, thoracic surgeons, and other specialists. The percentages of any complication and of any major complication differed statistically significantly across the four groups, with the lowest percentages in the electrophysiologist group. Among common, specific adverse events, electrophysiologists had the lowest rates of hematoma, lead dislodgement, pneumothorax, and cardiac arrest. Other outcomes occurred in 0.1 percent or less of patients, with zero to five events in at least one subgroup; thus the estimates are not reliable.

#### Comparative Studies

There is limited comparative evidence on early adverse events for ICDs with different device features or numbers of leads (Appendix Table 15 and Appendix Table 16). MADIT-CRT73 compared in-hospital and 30-day rates of adverse events in ICD and CRT-D recipients, which were as follows: coronary venous dissection with pericardial effusion (0% [ICD] vs. 0.5% [CRT-D]), pneumothorax (0.8 vs. 1.7%), infection (0.7 vs. 1.1%), and pocket hematoma requiring evacuation (2.5 vs. 3.3%). 30-day adverse events comparing ICD with CRT-D were also reported by RAFT: coronary sinus dissection (0 vs. 1.2%), hemothorax or pneumothorax (0.9 vs. 1.2%), pocket infection requiring intervention (1.8 vs. 2.4%), pocket hematoma requiring evacuation (1.2 vs. 1.6%) and lead dislodgement requiring revision (0.1 vs. 0.5%).74 Neither study reported between-group statistical findings, but there was a trend toward higher percentages in the CRT-D arm than in the ICD arm.

ADRIA (A+ versus DR Clinical Investigation of Arrhythmia Discrimination)122 compared in-hospital adverse events associated with receipt of a single-lead ICD with integrated atrial sensing rings versus a dual-chamber ICD. No statistical differences were found for pneumothorax (0.8% for both ICDs) or ventricular perforation (0 vs. 0.8%, respectively).

### Late Adverse Events from Cohort Studies

We identified 28 studies of 500 or more patients that reported late adverse events occurring 30 or more days after ICD implantation (Appendix Table 17).76,123-149 This includes ICD arms from MADIT II76) and SCD-Heft145 as well as four studies derived from one database, the Leiden University Medical Center Cardiology Information System (EPD-Vision)124,128,139,141 Table 14 presents a summary of the late adverse event rates across studies.

Table 14 Percentage of patients with early (in-hospital) adverse events in NCDR ICD database

Outcomes | No. Studies^*^ (Largest N) | Adverse Event Range
Any adverse event | 8 (356,515) | 2.77–3.55
Any serious adverse event | 5 (356,515) | 1.17–1.35
Any adverse event or death | 2 (268,701) | 1.5–3.37
Arteriovenous fistula | 6 (268,701) | <0.1
Cardiac arrest | 9 (356,515) | 0.26–0.34
Cardiac perforation | 7 (268,701) | 0.06–0.1
Cardiac valve injury | 4 (268,701) | <0.1
Conduction block | 6 (268,701) | 0.03–0.1
Coronary venous dissection | 6 (356,515) | 0.08–0.15
Drug reaction | 6 (268,701) | 0.09–0.11
Hematoma | 8 (356,515) | 0.84–1.1
Hemothorax | 8 (268,701) | 0.07–0.1
Infection related to device | 6 (268,701) | <0.1
Lead dislodgement | 8 (356,515) | 0.73–1.2
Myocardial infarction | 6 (268,701) | <0.1
Pericardial tamponade | 6 (268,701) | 0.07–0.1
Peripheral embolism | 6 (268,701) | <0.1
Peripheral nerve injury | 4 (268,701) | <0.1
Phlebitis, deep | 5 (268,701) | <0.1
Phlebitis, superficial | 6 (268,701) | 0.04–0.1
Pneumothorax | 9 (356,515) | 0.42–0.51
Stroke/cerebrovascular accident | 6 (268,701) | 0.05–0.1
Transient ischemic attack | 6 (268,701) | <0.1

* Data from Wei, 2011 PMID 21487093 are outliers and are not included. All patients in this study had B-type natriuretic peptide (BNP) measurement which may represent patients with heart failure. Also the study did not explicitly exclude patients with prior ICD.

In contrast with the studies in the NCDR ICD database, the literature overall had no standardization of outcome definitions across long-term studies. We tabulated device-and lead-related adverse events as they were reported (Appendix Table 19). Eight studies provided data on device-related events, namely malfunction requiring replacement or revision or dislocation.127,130,132,134,139,140,142,146 The duration of followup was 2.6 to 70 months. The percentage of patients with malfunction or dislocation ranged from <0.1 to 6.4 percent.

One study reported that 6.1 percent of patients with recalled ICD devices experienced device-related adverse events with a 70 month followup.146 (Appendix Table 20).

Sixteen studies provided data on lead-related adverse events, such as malfunction, failure, dislodgement, fracture, need for replacement, or revision or repositioning (Appendix Table 20).76,124,125,127,129-132,135-137,140-143,149 The rates of these events ranged from <0.1 to 19 percent. Twelve studies reported rates from <0.1 to only 3.9 percent and had followup of 1.5 to 86 months. One study, by Morrison, reported reported a 4-year lead survival rate of 98.7 percent.136 Four studies reported higher rates and had long followup periods (35 months, 43 months, 49 months and 8 years). Lead dysfunction was reported in 16.5 percent of patients at 35 months,129 and lead revisions, in 19 percent at 43 months.125 These two studies may have overlapping patient populations. High voltage lead defects were reported in 7.0 percent of patients with 49 month followup.143 In addition, van Rees 2012, which reported 3.9 percent lead failure at 41 months, reported a cumulative 11.5 percent rate of lead failure at 8 years, the longest followup time reported for this outcome.141

Seven studies provided data on lead-related adverse events for the recalled Sprint Fidelis leads with followup ranging from 32 to 86 months (Appendix Table 20). Five of these studies reported a failure or a malfunction rate of between 7.1 and 8.4 percent.123,126,131,144,147 The sixth study reported a 4-year lead survival rate of 87 percent,136 which corresponds at most to a 13 percent failure rate. A post hoc analysis of patients in RAFT who received Sprint Fidelis leads reports 5.5 percent of patients had lead failure over 39 months and a lead fracture rate of 1.65 percent per year.149

Twelve studies provided data on infection, with followup periods of 1.5 to 49 months (Appendix Table 21).76,124,127,128,130,132-134,138-141 The definition of infection varied across the studies, as did the severity and consequence of the observed cases. Additionally, it was not always possible to ascertain whether the infections reported in cohort studies included post-operative infection. Across all studies, the rate of infection ranged from 0.2 to 3.7 percent.

Four studies reported the rates of thrombosis (Appendix Table 21).133,134,143,145 Among patients in SCD-HeFT without atrial fibrillation or flutter at baseline 2.9 percent experienced a thromboembolic event.145 Three studies reported deep vein thrombosis rates of 0.2 to 1.0 percent with 1.5 to 49 month followup.133,134,143

#### Subgroup Analyses

We identified 12 articles that reported subgroup analyses of late (out of hospital) adverse events in ICD recipients (Appendix Table 22).123,126,132,134,135,138,142,144,147,149-151 Of these, 11 studies reported statistical comparisons among subgroups for at least one outcome. Five studies compared rates of adverse events between patients receiving ICDs for primary prevention versus those with ICDs for secondary prevention.123,132,142,144,147 No statistically significant differences were found between the two groups for surgical revision, lead dislodgement, recalled lead failure, or infection.

Four studies found statistically significantly higher rates of lead-related adverse events among women compared with men.123,126,135,144 For other outcomes and subgroups, the evidence is sparse, with only one study addressing each subgroup comparison or two or more studies showing inconsistent findings.

#### Comparative Studies

There is limited comparative evidence on late (out of hospital) adverse events for ICDs with different device features or numbers of leads (Appendix Table 15 and Appendix Table 16). These studies have limited followup which may under-appreciate the rate of adverse events. Two RCTs report rates of late adverse events in ICD groups versus CRT-D groups.73,111 MADIT-CRT reported the rates of total device-related adverse events as 5.2 vs. 4.5 per 100 device-months in ICD and CRT-D groups, respectively (without statistical comparison provided).73 In the MENDMI study of 80 patients, after 1 year of followup, the composite adverse event was 42 percent with ICD and 52 percent with CRT-D (not statistically significant).111 This prespecified composite outcome included LV lead dislodgement, postimplantation LV lead repositioning, permanent failure to deliver biventricular pacing, ventricular tachyarrhythmia, hospitalization due to cardiac causes and all-cause mortality.

ADRIA compared adverse events in patients who received a single-lead ICD with integrated atrial sensing rings to those with a dual-chamber ICD. At 1 year, ventricular lead–related adverse events were not statistically significantly different at 5.6 percent and 4.0 percent, respectively.122

### Inappropriate Shock

We identified fifteen studies which provided data on inappropriate shocks in a cohort of at least 500 patients receiving ICDs.51,125,129,130,135,136,152-160 Baseline information about these studies can be found in Appendix Table 17. The duration of followup ranged from 1 to 5 years. The percentage of patients experiencing inappropriate shocks was 3 to 21 percent overall (Table 14, Appendix Table 18). In four studies with 12 months of followup, percentages were 3 to 16 percent. For the other studies with 18 to 60 months followup, the percentage ranged from 8 to 21 percent. One study reported rates per year and found 2.4 percent of patients per year had inappropriate or unadjudicated shocks.51 MADIT-RIT found that programming of ICD therapies for tachyarrhythmias of ≥200 beats per minute or with a prolonged delay in therapy at ≥170 beats per minute, as compared with conventional programming, was associated with reductions in inappropriate shock.60

#### Subgroup Analyses

We identified 13 articles that reported subgroup analyses of inappropriate shock in ICD recipients (Appendix Table 22).93,125,129,135,148,150,151,153-155,159,161,162 All of these studies reported statistical comparisons for at least one subgroup comparison. Five studies compared rates of inappropriate shock between patients receiving ICDs for primary prevention versus those with ICDs for secondary prevention.129,148,153,159,162 Only one of these found a statistically significant difference with fewer shocks in the primary prevention group.153

Five studies found lower rates of inappropriate shocks in older patients.125,141,153,155,162 Age cut-offs varied between studies (more than 66.4 [the cohort mean age], 70, or 75 years, or per 10-year increase). In four of these, the difference was statistically significant. The fifth study did not report a statistical comparison. There was mixed data regarding the subgroup effect on inappropriate shock for single- vs. dual-chamber ICDs and for diabetes.

#### Comparative Studies

We identified one RCT and one nRCS that compare inappropriate shock in patients implanted with ICDs with different device features or numbers of leads (Appendix Table 15 and Appendix Table 16).122,156 ALTITUDE (the acronym is undefined) reported a 5-year rate of inappropriate shock as 16 percent among ICD recipients and 17 percent among CRT-D recipients (no statistical comparison provided).156 ADRIA (described above) reported rates of inappropriate shock as 5.6 percent in both single- and dual-chamber ICD groups.122

### Summary

The rates of adverse events captured early in the NCDR ICD database range from 2.8 to 3.6 percent and the serious adverse event rates ranges from 1.2 to 1.35 percent (Table 15). The most common early adverse events are lead dislodgement (in 0.7 to 1.2 percent of patients) and hematoma (in 0.8-1.1 percent). Other early in-hospital adverse events occur in 0.5 percent of patients or less. The strength of evidence for early adverse events is high (Table 12).

Table 15 Percentage of patients with late (out of hospital) adverse events and inappropriate shocks (excluding studies of recalled leads or devices)

Outcomes | No. Studies/Cohorts^*^ (N) | Adverse Event Range
Device- and lead-specific adverse events
Total device-related adverse event | 2 (1,820) | 4.5-5.2/100 device-mo
ICD mechanical complications | 1 (38,992) | 4.2%
ICD replacement | 3 (5,593) | <0.1-2.6%; 0.1/100 pt-yr
ICD revision | 2 (42,245) | 2.2-6.4%; 5.2/100 pt-yr
ICD mechanical complication | 1 (38,992) | 4.2%
Lead-related adverse event, total | 3 (15,636) | 3.6-5.6%
Lead malfunction | 3 (20,242) | 2.4-3.9%; 1.14-1.2/100 pt-yr
Lead (high voltage) defect | 1 (903) | 7.0%
Lead problem requiring surgery | 1 (742) | 1.8%
Lead failure | 3 (4,246) | 0.2-3.8%; 1.4/100 pt-yr
Lead fracture requiring revision | 1 (1,060) | 3.4%
Lead fracture requiring ICD explants | 1 (1,339) | <0.1%; 0.07/100 pt-yr
Lead dislodgement | 5 (27,084) | 0.6-3.1%; 1.4-2.8/100 pt-yr
Lead replacement | 3 (15,697) | 0.4-1.0%; 0.34-3.4/100 pt-yr
Lead revision or repositioning | 5 (12,995) | 0.3-19%; 0.8/100 pt-yr
Infection
Infection, general | 2 (199,207) | 1.2-2.7%
Infection of ICD device | 2 (10,561) | 0.9%; 4.2/100 pt-yr
Infection requiring ICD removal | 4 (531,959) | 0.5-3.7%; 0.7/100 pt-yr
Infection of lead requiring antibiotics | 1 (1,060) | 0.5%
Infection requiring surgery, nonfatal | 1 (742) | 0.7%
Pocket infection | 1 (667) | 1.0%; 1.2/100 pt-yr
Pocket infection requiring debridement | 1 (3,340) | 1.0%
Sepsis/severe infection | 2 (12,868) | 0.2% 1^st^ yr: 98.8/100 pt-yr Following: 63.9/100 pt-yr
Thrombosis
Deep vein thrombosis | 1 (38,992) | 1.0%
Subclavian vein thrombosis | 2 (4,243) | 0.2-0.9%
Thromboembolic event, any | 1 (681) | 2.9%
Inappropriate shocks
Inappropriate shocks | 21 (212,312) | 3-21%

ICD = implanted cardiac defibrillator, mo = months; N = number of patients, pt-yr = patient-years.

* Single cohort studies and cohorts (study arms) from comparative studies are counted individually

Higher rates of early adverse events have been shown in the following subgroups: patients implanted with dual-chamber ICDs or CRT-Ds (vs. single-chamber ICDs); patients who are older, female, or have ESRD; patients implanted by physicians with a lower implantation volume or by nonelectrophysiologists; and patients implanted at hospitals with a lower implantation volume.

Regarding late adverse events which were captured usually after the initial hospitalization for implantation, the percentage of patients with device-related adverse events with variable definitions ranged from <0.1 to 6.4 percent for followup durations of 2 to 49 months. For lead-related adverse events (malfunction, failure, dislodgement, fracture, or need for replacement or revision, or repositioning) the rates ranged from <0.1 to 3.9 percent of patients with followup durations from 1.5 to 40 months, but studies with longer followup times (35 to 96 months) reported rates of 7.0 to 19 percent. Failure of the Sprint Fidelis lead was reported in approximately 6 to 8 percent of patients followed for up to 7 years. Infections, variably defined, were reported in 0.2 to 3.7 percent of patients with followup of 1.5 to 49 months. There are limited data on thrombosis in long-term followup:one study reported a rate of thromboemolic events of 2.9 percent, with a 46 month followup, and three studies reported deep vein thrombosis rates of 0.2 and 1 percent, with followup periods of 1.5 to 49 months. Given the limited number of studies for each outcome and the variable definitions and methods of ascertainment, the strength of evidence for late adverse events is low. Subgroup analyses show female sex to be associated with more lead-related adverse events.

The percentage of patients who experience at least one inappropriate shock ranged from 3 to 21 percent for followup between 1 and 5 years. The strength of evidence for inappropriate shocks was moderate with good data ascertainment but imprecision due to varying percentages across studies. Subgroup analyses show older age to be associated with fewer inappropriate shocks.

The data from five comparative studies for early and late adverse events and inappropriate shock fail to show differences across ICDs with different device features.

Table 16 ICDs for Primary Prevention of SCD: Strength of evidence domains

Outcome | Study Design: No. Studies (N) | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Other Issues | Strength of Evidence and Findings
Major outcomes
Early (in-hospital) AE | | Low | Direct | Consistent | Precise | Low | None | High
- Any AE | Registry: 9 (356,515^*^) | | | | | | | Any AE: 2.8-3.6%
- Serious AE | Registry: 7 (356,515^*^) | | | | | | | Serious AE: 1.2-1.35%
- Lead dislodgement | RCT:1, Registry: 9 (358,313^*^) | | | | | | | Lead dislodgement: 0.7-1.2%
- Hematoma | RCT:2, Registry: 9 (360,133^*^) | | | | | | | Hematoma: 0.8-1.1%
- Multiple^†^ | | | | | | | | All other AE: <0.5%
Late (out of hospital) AE | | Low | Direct | Inconsistent | Imprecise | Suspected | None | Low
- Total AE^‡^ | RCT: 1 (80) | | | | | | | Total AE^§^: ICD vs. CRT-D 42% vs. 52% (NS) for 1 yr F/U
- Device-related AE | Cohort: 9 (64,174) | | | | | | | Device-related AE: <0.1-6.4% for 2-49 mo F/U
- Lead-related AE | RCT: 1, Cohort: 23 (57,234^*^) | | | | | | | Lead-related AE: <0.1–3.9% for 1.5-41 mo F/U
- Infection | Cohort: 15 (65,449^*^) | | | | | | | Infection: 0.2–3.7% for 1.5-49 mo F/U
- Thrombosis | Cohort: 5 (45,789) | | | | | | | Thrombosis: 0.2–2.9% for 1.5–49 mo F/U
Inappropriate shock | RCT: 1, Cohort: 21 (212,312^*^) | Low | Direct | Consistent | Imprecise | Low | None | Moderate Inappropriate shock: 3-21% for 1-5y F/U

[underlined: Abbreviations:] AE=adverse event; DVT=Deep vein thrombosis; F/U=followup; ICD: implantable cardioverter-defibrillator; mo=month; No.=Number; RCT=randomized, controlled trial; SCD=sudden cardiac death; y=year.

* Largest independent N

† Study design is registry unless otherwise noted. Outcome: No. of studies (largest independent N): Any AE or death: 2 (268,701), Arteriovenous fistula: 7 (268,701), Cardiac arrest: 10 (356,515), Cardiac perforation: 1 RCT, 8 Registry (268,950), Cardiac valve injury: 4(268,701), Conduction block: 7 (268,701), Coronary venous dissection: 2 RCT, 7 Registry (360,133), Drug reaction: 7 (268,701), Hematoma: 1 RCT, 9 Registry (358,335), Hemothorax: 9 (268,701),Hemothorax or pneumothorax: 1 RCT (1798), Infection related to device: 2 RCT, 8 registry (272,319), Myocardial infarction: 7 (268,701), Pericardial tamponade: 7 (268,701), Peripheral embolism: 7 (268,701), Peripheral nerve injury: 5(268,701), Phlebitis – deep: 6(268,701), Phlebitis – superficial: 7 (268,701), Pneumothorax: 2 RCT, 10 Registry (358,584), Pocket problems requiring revision: 1 RCT (1798), Stroke/CVA: 7 (268,701), Transient ischemic attack: 7 (268,701).

‡ Outcome of interest for comparative studies.

§ Left ventricular lead dislodgement, postimplantation left ventricular lead repositioning, permanent failure to deliver biventricular pacing, ventricular tachyarrythmia, hospitalization due to cardiac causes and all-cause mortality.

## Key Question 3 Which Patients Have Been Included in Comparative Studies of ICDs for Primary Prevention of SCD?

For Key Question 3, we reviewed the eligibility criteria for all 18 studies contributing data to Key Question 1.

### Key Question 3a What Were Eligibility Criteria for Patients in Studies Included for Key Question 1? How Were Patients Evaluated and What Diagnostic Tests and Algorithms Were Used to Select Patients?

#### Eligibility Criteria

We categorized the studies according to whether they included only a) patients with ischemic cardiomyopathy and MIs that occurred at least 30 days before ICD implantation (henceforth called “remote MIs”), b) patients with nonischemic cardiomyopathy only, c) patients with either ischemic or nonischemic cardiomyopathy and remote MIs, and d) patients with ischemic cardiomyopathy and either MIs that occurred more recently than 30 days before ICD implantation (henceforth called “recent MIs”) or coronary revascularization (i.e., patients who would not meet current CMS criteria for ICD implantation for primary prevention of SCD). Note that a study was considered to address remote MI only if all patients had their MI at least 30 days before ICD placement; if the range of timing of MI included some time points of less than 30 days before implantation, the population was considered to have recent MI. Table 17 provides an overview of the eligibility criteria across studies.

Table 17 Eligibility criteria in comparative study

Study Author Year | IDCM & Documented MI | NIDCM >3 mo | NYHA II/III | NYHA IV/CRT | LVEF ≤35% | No MI <40 d | No Revasc <3 mo | No shock / hTN | Revasc not indicated | No brain damage | Exp Surv >1 y
ICD vs. No ICD
AMIOVIRT Strickberger 2003 | -- | Yes (no time^*^) | No (also Class I) | -- | Yes | Yes (implied) | Yes (implied) | nd | Yes | nd | nd
CABG-Patch Bigger 1997 | No (MI not required) | -- | nd | nd | Yes | nd | No | nd | No (al having CABG) | nd | Yes
CAT Bänsch 2002 | -- | No (≤9 mo) | Yes | -- | Yes | Yes | Yes (implied) | nd | Yes | nd | nd
Chan 2009 | Yes | Yes | nd | nd | Yes | No (No MI <30 d) | Yes (no time^*^) | nd | nd | nd | Yes
COMPANION Bristow 2004 | No (MI not required) | Yes (no time^*^) | Yes | Yes | Yes | nd | nd | nd | nd | nd | nd
DEFINITE Kadish 2004 | -- | Yes (no time^*^) | No (also Class I) | -- | Yes | Yes (implied) | Yes (implied) | nd | Yes | nd | nd
DINAMIT Hohnloser 2004 | Yes | -- | No (also Class I) | -- | Yes | No (All MI ≤40 d) | Yes (implied) | nd | Yes | nd | Yes (“limited”)
Fonarow 2000 | -- | Yes (no time^*^) | Yes | Maybe (nd re: CRT) | Yes | Yes | Yes (implied) | nd | nd | nd | nd
IRIS Steinbeck 2009 | Yes | -- | No (also Class I) | -- | No (≤40%) | No (All MI ≤31 d) | nd | nd | Yes | nd | Yes (“severe”)
MADIT Moss 1996 | Yes | -- | No (also Class I) | -- | Yes | No (No MI <21 d) | No (<2 mo) | nd | Yes | Yes | Yes
MADIT II Moss 2002 | Yes | -- | No (also Class I) | -- | Yes | No (No MI <1 mo) | Yes | Yes | Yes | Yes | Yes
Mezu 2011 | No (MI not required) | Yes (no time * ) | No (also Class I) | -- | Yes | No (any time) | No (implied) | nd | No (implied) | No | No
OPTIMIZE-HF / GWTG-HF Hernandez 2010 | No (MI not required) | Yes (no time * ) | nd | nd | Yes | nd | nd | nd | nd | nd | nd
SCD-HeFT Bardy 2005 | No (MI not required) | Yes (no time^*^) | Yes | -- | Yes | nd | nd | nd | nd | nd | nd
ICD vs. CRT-D
Diab 2011 | No (MI not required) | Yes (no time^*^) | Yes | Yes | Yes | nd | nd | nd | Yes | nd | No (>6 mo)
MADIT-CRT Moss 2009 | Yes | Yes | No (also Class I) | -- | Yes | Yes | Yes | nd | Yes | Yes | Yes
MENDMI Chung 2010 | Yes | -- | No (also Class I) | -- | Yes | No (all MI ≤14 d) | Yes | nd | nd | nd | No (>6 mo)
RAFT Tang, 2010 21073365 | No (MI not required) | Yes | Yes | -- | Yes | nd | nd | nd | nd | nd | nd

Explanation of headers:

IDCM & Documented MI: Ischemic dilated cardiomyopathy and documented prior myocardial infarction

NIDCM >3 mo: Nonischemic dilated cardiomyopathy >3 months (with or without prior myocardial infarction)

NYHA II/III: New York Heart Association Class II or III heart failure

NYHA IV/CRT: NYHA Class IV heart failure and meet all current CMS coverage requirements for a cardiac resynchronization therapy device

LVEF ≤35%: Left ventricular ejection fraction ≤35%

No MI <40 d: No acute myocardial infarction within the past 40 days

No Revasc <3 mo: No coronary artery revascularization (coronary artery bypass graft or percutaneous transluminal coronary angioplasty) within the past 3 months

No shock / hTN: No cardiogenic shock or symptomatic hypotension while in a stable baseline rhythm

Revasc not indicated: No clinical symptoms or findings that would make them a candidate for coronary revascularization

No brain damage: No irreversible brain damage from preexisting cerebral disease

Exp Surv >1 y: No disease, other than cardiac disease (e.g. cancer, uremia, liver failure), associated with a likelihood of survival <1 year

Abbreviations: -- = this factor was not part of inclusion criteria (e.g., AMIOVIRT trial excluded patients with ischemic dilated cardiac disease), CABG = coronary artery bypass graft, CRT-D = cardiac resynchronization therapy and implanted cardioverter defibrillator, ICD = implanted cardioverter defibrillator, nd = not documented.

* Eligibility criteria did not include duration of NIDCM or time since revascularization

##### Studies of Patients with Ischemic Cardiomyopathy and Remote MI (>30 days before ICD)

MADIT and MADIT II compared ICD versus no ICD in patients with ischemic cardiomyopathy and remote MI (Appendix Table 23).42,76 Both studies were conducted in the US and Europe. MADIT included adults aged 25 to 80 years; MADIT II included adults over 21 years. Both enrolled only patients in NYHA Classes I, II, and III. The LVEF inclusion criterion for the original MADIT was ≤35 percent. MADIT II was more restrictive, including only those with an LVEF ≤30 percent.

##### Studies of Patients with Nonischemic Cardiomyopathy

Four studies enrolled patients with nonischemic cardiomyopathy (Appendix Table 23).91,99,103,106 Two RCTs (DEFNITE and CAT) and one nRCS (Fonarow 2000) compared ICD versus no ICD (Appendix Table 23).91,99,106 The third RCT (AMIOVIRT) compared ICD versus amiodarone.103 The studies of ICD versus no ICD were conducted in the US, and the single study of ICD versus amiodarone was conducted in Germany.

Two studies (CAT and AMIOVIRT) enrolled adults over 18 years of age, but in the CAT study, the upper limit for age was 70 years. The other studies did not set an age restriction for enrollment.

Two RCTs (DEFINITE and AMIOVIRT) enrolled patients in NYHA Classes I, II, and III. The single nRCS (Fonarow 2000) included only those with Classes III and IV. The CAT study restricted its inclusion to those with Classes II and III only.

Two studies (DEFINITE, AMIOVIRT) enrolled only patients with an LVEF ≤35 percent; Fonarow 2000 included patients with LVEF <35 percent. The CAT study was restricted to those with an LVEF ≤30 percent.

##### Studies of Patients with Mixed Ischemic and Nonischemic Cardiomyopathy

Five RCTs (COMPANION, SCD-HeFT, MADIT-CRT, RAFT and Diab 2011) and three nRCSs (Chan 2009, OPTIMIZE-HF/GWTG-HF, and Mezu 2011) enrolled a mixed population of ischemic and nonischemic cardiomyopathy (Appendix Table 23).51,73,95,105,107,108,112,149 The three nRCSs (Chan 2009, OPTIMIZE-HF/GWTG-HF and Mezu 2011) examined the comparison of ICD versus no ICD105,107,108 while a single RCT (SCD-HeFT) compared ICD vs. amiodarone.7 Another RCT (COMPANION) compared CRT-D versus a control95 and three additional RCTs (MADIT-CRT, RAFT, and Diab 2011) looked at the comparison of ICD versus CRT-D.73,112,149 The studies of ICD or CRT-D versus no ICD or amiodarone were conducted in the US. Of the three studies examining ICD versus CRT-D, one was conducted in the US, Canada, and Europe, another in Europe, Canada and Australia, and the third was conducted in the United Kingdom.

One (Chan 2009) of the three nRCSs comparing ICD versus no ICD enrolled patients over 18 years of age. OPTIMIZE-HF/GWTG-HF included patients aged 65 to 84 years while Mezu 2011 restricted its enrollment to only those over 80 years of age. Only one of the RCTs (MADIT-CRT) examining ICD versus CRT-D reported an inclusion criterion for age (> 21 years). COMPANION, RAFT, and SCD-HeFT also did not set an age restriction.

Of the four studies reporting on ICD or CRT-D versus no ICD, two (Chan 2009 and OPTIMIZE-HF/GWTG-HF) did not have an inclusion criterion regarding NYHA class. The remaining two (COMPANION, Mezu 2011) included those with only NYHA Classes III and IV, or Classes I, II, and III respectively. SCD-HeFT included only Classes II and III. One study (MADIT-CRT) of ICD versus CRT-D enrolled only patients in NYHA Classes I and II, while the another enrolled those in NYHA Classes II and III (RAFT), and a third (Diab 2011) enrolled only those in Classes III and IV. In all but two studies, the cutoff for the LVEF was ≤35 percent. The remaining studies (MADIT-CRT and RAFT) were restricted to only patients with an LVEF ≤30 percent. Two RCTs of ICD versus no ICD (COMPANION and Chan 2009) required the patients to have a QRS interval >120 ms. All studies of ICD versus CRT-D set a limit on the QRS interval for enrollment; two (in RAFT and Diab 2011) were ≥120 ms while the other (in MADIT-CRT) was ≥130 ms.

##### Studies of Patients with Ischemic Cardiomyopathy and Recent MI (<30 days before ICD) or Revascularization

Three RCTs (DINAMIT, IRIS, and MENDMI) enrolled patients with ischemic cardiomyopathy and recent MI (<30 days before ICD implantation)98,102,111 and a fourth trial (CABG-Patch) enrolled patients with ischemic cardiomyopathy who were undergoing coronary revascularization.94 The four studies were conducted in multiple countries, including the US and Germany (Appendix Table 23). Three (DINAMIT, IRIS, CABG-Patch) had an age restriction as part of their inclusion criteria, enrolling only those younger than 80 years of age.

The three trials of patients with recent MIs (i.e., with at least one patient, but not necessarily all, who had an MI less than 30 days before ICD placement) included those whose MIs occurred either between 6 and 40 days before ICD implantation, 5 and 31 days before, and 3 and 14 days before.

Two studies (DINAMIT and MENDMI) restricted their enrollment by NYHA Class I, II, and III. Three studies (DINAMIT, MENDMI, and CABG-Patch) required an LVEF ≤35 percent, another study (IRIS) included patients with an LVEF ≤40 percent. Two studies specified an inclusion criterion for QRS interval: one (CABG-Patch) set its cutoff at ≥114 ms; the other (MENDMI), <120 ms.

##### Summary: Eligibility

The two studies of patients with ischemic cardiomyopathy whose MIs occurred at least 30 days prior to ICD implantation included adults with NYHA Class I, II, or III with an LVEF either ≤30 percent or ≤35 percent.

The four studies of patients with nonischemic cardiomyopathy included adults (though one study was restricted to adults 70 years or younger) with a variety of NYHA class criteria. Two RCTs included patients with NYHA Classes I, II, and II; one RCT included only those with Classes II and III; and the nRCS restricted enrollment to Classes III and IV. Three of the studies included patients with LVEF either less than or less than or equal to 35 percent. One trial restricted to LVEF ≤30 percent.

The plurality of studies (five RCTs and two nRCSs) included both patients with ischemic and nonischemic cardiomyopathy. The RCTs included essentially all eligible adults. The two nRCSs, on the other hand, were restricted to older adults, either aged 65 to 84 years or over 80 years. The studies were heterogeneous as to which NYHA Classes were included (I-IV, I-III, I and II, II and III, or III and IV). All but two studies included patients with LVEF either less than or less than or equal to 35 percent; two trial restricted to LVEF ≤30 percent. Four of the trials used QRS interval eligibility criteria of either greater than or greater than or equal to 120 ms or, for one trial, ≥130 ms.

Four trials had eligibility that clearly would not meet current CMS criteria for ICD use for primary prevention of SCD. Three trials included patients with recent MIs, either ≤40, ≤31, or ≤14 days since their MI. The fourth trial was restricted to patients undergoing CABG.

#### Diagnostic Tests and Algorithms Used to Select Patients

Table 18 displays the diagnostic tests that were used in the RCTs to select patients. No trial explicitly used an algorithm (other than electrophysiology testing, which is described below). All trials used LVEF criteria for eligibility and measured LVEF with a variety of tests, though usually echocardiography; other tests included angiography and radionuclide scanning. All studies except CABG-Patch determined the patients' NYHA class of heart failure. The CRT-D studies and CABG-Patch used QRS intervals on 12-lead electrocardiograms (ECGs) or signal-averaged ECGs; other ICD trials did not.

Table 18 Diagnostic tests used to select patients (RCTs only)^*^

Study | LVEF Measured (Test) | QRS Measured | NYHA Class Determined | NSVT | EP Study | Coronary Stenosis (Test) | Other
ICD vs. No ICD
AMIOVIRT Strickberger 2003 | Yes (nd) | No | Yes | Yes (multiple^†^) | No | Yes, implied (nd) | No
CABG-Patch Bigger 1997 | Yes (nd) | Yes (SA ECG) | No | No | No | Yes, implied (angiography) | No
CAT Bänsch 2002 | Yes (angiography) | No | Yes | Yes (Holter) | No | Yes (angiography) | No
COMPANION Bristow 2004 | Yes (echo) | Yes (ECG) | Yes | No | No | No | No
DEFINITE Kadish 2004 | Yes (nd) | No | Yes | Yes (Holter or telemetry) | No | Yes (angiography or ETT) | No
DINAMIT Hohnloser 2004 | Yes (multiple^‡^) | No | Yes | No | No | No | RR interval (Holter)
IRIS Steinbeck 2009 | Yes (echo) | No | Yes | Yes (Holter) | No | No | No
MADIT Moss 1996 | Yes (multiple^‡^) | No | Yes | Yes (multiple^§^) | Yes | No | No
MADIT II Moss 2002 | Yes (multiple^‡^) | No | Yes | No | No | No | No
SCD-HeFT Bardy 2005 | Yes (nd) | No | Yes | Yes (Holter) | No | No | 6 min walk, CXR
ICD vs. CRT-D
Diab 2011 | Yes (echo) | Yes (nd) | Yes | No | No | Yes (ETT) | Mech dyssynch (echo or TDI) LVEDD (echo)
MADIT-CRT Moss 2009 | Yes (echo) | Yes (nd) | Yes | No | No | No | No
MENDMI Chung 2010 | Yes (echo) | Yes (ECG) | Yes | No | No | No | WMA (echo)
RAFT Tang, 2010 21073365 | Yes (nd) | Yes (nd) | Yes | No | No | No | 6-min walk

6 min walk = 6 minute walk test, CRT-D = cardiac resynchronization therapy with defibrillator, CXR = chest radiography, ECG = electrocardiography, Echo = echocardiography, EP = electrophysiology, ETT = exercise tolerance test (stress test), Holter = 24-hour Holter monitor, ICD = implanted cardiac defibrillator, LVEDD = left ventricle end-diastolic diameter, LVEF = left ventricle ejection fraction, nd = not documented, Mech dyssynch = mechanical ventricular dyssynchrony, NSVT = nonsustained ventricular tachycardia, NYHA = New York Heart Association, SA ECG = signal averaged ECG, RR interval = time between R waves on ECG, TDI = tissue Doppler imaging, WMA = left ventricular wall motion abnormality.

* Excluding laboratory tests, symptoms, past medical history, or physical examination findings.

† ECG, telemetry or Holter monitor

‡ Angiography, radionuclide scanning, or echocardiography

§ ECG, Holter, or exercise ECG.

Six of the 10 ICD versus no ICD trials tested patients for nonsustained VT, most frequently with 24-hour ambulatory Holter monitoring, but also with telemetry, 12-lead ECG, or exercise ECG (stress testing). Only MADIT reported using electrophysiology testing. MADIT II specifically addressed whether electrophysiology testing could be avoided when determining whether ICD placement would be of value.

Only four of the 10 ICD versus no ICD trials and one of the three CRT-D versus ICD trials explicitly tested for coronary stenosis, mostly with coronary angiography or exercise testing. A few trials used other unique diagnostic tests, as listed in Table 17.

##### Summary: Tests Used

There was heterogeneity regarding which diagnostic tests were used to determine study eligibility across trials. (Table 18) All RCTs used LVEF criteria, but the studies used different specific tests (though most were based on echocardiography). NYHA class was also determined in all patients (except in one older trial). The trials of CRT-D used QRS interval data for eligibility; most other trials did not. Most of the RCTs of ICD versus no ICD tested all patients for nonsustained VT, but with different specific diagnostic tests. Only one RCT reported performing electrophysiology testing in all patients. Only 4 of the 13 RCTs explicitly tested for coronary stenosis, mostly with coronary angiography or exercise testing.

### Key Question 3b Among Patients in Studies Included for Key Question 1, What Was the Likelihood of SCD or Ventricular Tachyarrhythmia, as Measured by Total Shocks for Those with ICDs or Episodes of SCD for Those without ICDs?

Five RCTs42,51,94,99,103 and one nRCS (Fonarow 2000^106^) provided data for total shocks or appropriate shocks in patients with an ICD. Some studies provided the data as total number of shocks; others, as number of patients receiving any shock or patients receiving only inappropriate shocks. The data are summarized in Table 19. In the first year after ICD implantation, between about one-quarter and one-half of patients had a shock. The percentage of patients who had a shock rose consistently with time since ICD implantation. Four of the studies that reported numbers of shocks (SCD-HeFT, Fonarow 2000, MADIT, CABG-Patch) described the percentage of patients receiving shocks over time and found progressively increasing percentages. Two of the trials (MADIT and CABG-Patch) report survival curves showing that about 50 percent of patients have a shock within the first year, after which the rate of patients having their first shock slows but continues to rise to approximately 70 percent at 4 years (CABG-Patch) and approximately 90 percent at 5 years (MADIT). The studies that reported appropriate shocks revealed similar patterns as for total shocks, though, as expected, with lower rates of appropriate shocks than total shocks.

Table 19 Patients with any shock from ICD and sudden cardiac deaths (with no ICD)

Study Author, Year PMID, Country | Intervention (Control) | Patients with an ICD who received any shock [appropriate shocks] | Patients with no ICD with SCD
5 y
AMIOVIRT Strickberger, 2003 12767651, US | ICD (Amiodarone) | nd total [31% [16/51) appropriate] | 3.8% (2/52)
4 y
SCD-HeFT Bardy, 2005 15659722, US | ICD (Amiodarone) | 31% (259/829) any shock; 7.5%/y [21% (177/829) appropriate; 5.1%/y] | nd
3 y
DINAMIT Hohnloser, 2004 15590950, Multi | ICD (No ICD) | nd | 8.5%; 3.5%/y (29/342)
IRIS Steinbeck, 2009 19812399, Germany | ICD (No ICD) | nd | 13.2% (60/453)
2 y
CABG-Patch Bigger, 1997 9371853, US and Germany | ICD (No ICD) | 57% actuarial risk (N=428) any shock | nd
DEFINITE Kadish, 2004 15152060, US | ICD (No ICD) | nd any shock^*^ [18% (41/229) appropriate] | 6.1% (14/229)
Fonarow, 2000 10760339, US | ICD (Control) | nd any shock^†^ [40% (10/25) appropriate (55% actuarial risk)] | nd
MADIT Moss, 1996 8960472, US and EU | ICD (No ICD) | 60% (54/90) any shock | 12.9% (13/101)
1 y
CAT Bänsch, 2002 11914254, Germany | ICD (Control) | nd | 0% (0/50)
CABG-Patch Bigger, 1997 9371853, US and Germany | ICD (No ICD) | 50% actuarial risk (N=428) any shock | nd
Fonarow, 2000 10760339, US | ICD (Control) | 27% actuarial risk (N=25) any shock | nd

1°=primary, CABG=coronary artery bypass graft, EU=Europe, ICD=implantable cardiac defibrillator, LVEF=left ventricular ejection fraction, MI=myocardial infarction, nd=not documented, NYHA=New York Heart Association, RCT=randomized controlled trial, UK, United Kingdom, US=United States.

* 49 patients received inappropriate shocks; no data on how many patients in any shock received shocks.

† 3 patients received inappropriate shocks; no data on how many patients in any shock received shocks.

Six RCTs reported on the episodes of SCDs in patients without an ICD.42,91,98,99,102,103 CAT reported no SCDs at 1 year. At 2 years, DEFINITE reported episodes in 6.1 percent of patients while MADIT reported episodes in 13 percent. At 3 years, DINAMIT and IRIS reported SCDs in 8.5 and 13 percent of their non-ICD patients, respectively. The study with the longest followup (5 years), AMIOVIRT, reported SCD in only 4 percent of patients at the end of followup. There was no clear trend for increasing likelihood of SCD with longer followup time across the six studies, but within the three RCTs that presented survival curves (DINAMIT, IRIS, and DEFINITE), there appeared to be fairly steady rates of SCD for about 3 to 6 years after randomization.

#### Summary: Risk of SCD

The six studies that provided data for total or appropriate ICD shocks found that patients in these trials were very likely to have a shock during followup. The majority of the first episodes of being shocked appear to occur within the first year after ICD implantation. The six RCTs that reported SCD in patients without an ICD included with a likelihood of SCD between about 4 and 13 percent during the 2 to 5 years after randomization. Rates of SCD over time appeared to be fairly steady.