# References

1 Adabag AS, Luepker RV, Roger VL, et al. Sudden cardiac death: epidemiology and risk factors. Nat Rev Cardiol. Apr. 2010;7(4):216-25. [pmid: 20142817].
2 Epstein AE, DiMarco JP, Ellenbogen KA, Estes NA III, Freedman RA, Gettes LS, et al. American College of Cardiology/American Heart Association Task Force on Practice Guidelines. Developed in collaboration with the American Association for Thoracic Surgery and Society of Thoracic Surgeons. [Erratum appears in Circulation.2009 Aug 4; 120(5):e34-5]. Circulation. 5. 27. 2008;117:e350-e408. [pmid: 18483207].
3 Lloyd-Jones D, Adams RJ, Brown TM, Carnethon M, Dai S, De Simone G, Ferguson TB, et al. Executive summary: heart disease and stroke statistics--2010 update: a report from the American Heart Association. [Erratum appears in Circulation. 2010 Mar 30;121(12):e259]. Circulation. 2. 23. 2010;121:948-954. [pmid: 20177011].
4 Myerburg RJ, Reddy V, Castellanos A. Indications for implantable cardioverter-defibrillators based on evidence and judgment. J Am Coll Cardiol. 8. 25. 2009;54:747-763. [pmid: 19695452].
5 Rea TD, Page RL. Community approaches to improve resuscitation after out-of-hospital sudden cardiac arrest. Circulation. 3. 9. 2010;121:1134-1140. [pmid: 20212292].
6 Zipes DP, Camm AJ, Borggrefe M, Buxton AE, Chaitman B, Fromer M, Gregoratos G, et al. ACC/AHA/ESC 2006 Guidelines for Management of Patients With Ventricular Arrhythmias and the Prevention of Sudden Cardiac Death: a report of the American College of Cardiology/American Heart Association Task Force and the European Society of Cardiology Committee for Practice Guidelines: developed in collaboration with the European Heart Rhythm Association and the Heart Rhythm Society. Circulation. 9. 5. 2006;114:e385-e484. [pmid: 16935995].
7 American Heart Association: 2001 Heart and Stroke Statistical Update. 2000.
8 Epstein FH, Pisa Z. International comparisons in ischemic heart disease mortality. Proc.Conf.Decline in Coronary Heart Disease Mortality. DHEW, NIH Publication No. 79-1610. U.S.Government. 1979:58-88.
9 Escobedo LG, Zack MM. Comparison of sudden and nonsudden coronary deaths in the United States. Circulation. 6. 1. 1996;93:2033-2036. [pmid: 8640979].
10 Zheng ZJ, Croft JB, Giles WH, Mensah GA. Sudden cardiac death in the United States, 1989 to 1998. Circulation. 10. 30. 2001;104:2158-2163. [pmid: 11684624].
11 Deo R, Albert CM. Epidemiology and genetics of sudden cardiac death. Circulation. 1. 31. 2012;125:620-637. [pmid: 22294707].
12 Kuller L, Lilienfeld A, Fisher R. An epidemiological study of sudden and unexpected deaths in adults. Medicine (Baltimore). 1967;46:341-361. [pmid: 6043997].
13 Luu M, Stevenson WG, Stevenson LW, Baron K, Walden J. Diverse mechanisms of unexpected cardiac arrest in advanced heart failure. Circulation. 1989;80:1675-1680. [pmid: 2598430].
14 Myerburg RJ, Kessler KM, Castellanos A. Sudden cardiac death. Structure, function, and time-dependence of risk. Circulation. 1992;85. Suppl-10. [pmid: 1728501].
15 Zipes DP, Wellens HJ. Sudden cardiac death. Circulation. 11. 24. 1998;98:2334-2351. [pmid: 9826323].
16 Survivors of out-of-hospital cardiac arrest with apparently normal heart. Need for definition and standardized clinical evaluation. Consensus Statement of the Joint Steering Committees of the Unexplained Cardiac Arrest Registry of Europe and of the Idiopathic Ventricular Fibrillation Registry of the United States. Circulation. 1997;95:265-272. [pmid: 8994445].
17 Fairbanks RJ, Shah MN, Lerner EB, Ilangovan K, Pennington EC, Schneider SM. Epidemiology and outcomes of out-of-hospital cardiac arrest in Rochester, New York. Resuscitation. 2007;72:415-424. [pmid: 17174021].
18 Nichol G, Thomas E, Callaway CW, Hedges J, Powell JL, Aufderheide TP, Rea T, Lowe R, Brown T, Dreyer J, Davis D, Idris A, Stiell I, Resuscitation Outcomes Consortium. Regional variation in out-of-hospital cardiac arrest incidence and outcome. [Erratum appears in JAMA. 2008 Oct 15;300(15):1763]. JAMA. 9. 24. 2008;300:1423-1431. [pmid: 18812533].
19 Fox CS, Evans JC, Larson MG, Lloyd-Jones DM, O'Donnell CJ, Sorlie PD, Manolio TA, Kannel WB, Levy D. A comparison of death certificate out-of-hospital coronary heart disease death with physician-adjudicated sudden cardiac death. Am.J Cardiol. 4. 1. 2005;95:856-859. [pmid: 15781015].
20 Hinkle LE Jr., Thaler HT. Clinical classification of cardiac deaths. Circulation. 1982;65:457-464. [pmid: 7055867].
21 Connolly SJ, Gent M, Roberts RS, Dorian P, Roy D, Sheldon RS, Mitchell LB, Green MS, Klein GJ, O'Brien B. Canadian implantable defibrillator study (CIDS) : a randomized trial of the implantable cardioverter defibrillator against amiodarone. Circulation. 3. 21. 2000;101:1297-1302. [pmid: 10725290].
22 Cairns JA, Connolly SJ, Roberts R, Gent M. Randomised trial of outcome after myocardial infarction in patients with frequent or repetitive ventricular premature depolarisations: CAMIAT. Canadian Amiodarone Myocardial Infarction Arrhythmia Trial Investigators. [Erratum appears in Lancet 1997 Jun 14;349(9067):1776]. Lancet. 3. 8. 1997;349:675-682. [pmid: 9078198].
23 Goldberger JJ, Buxton AE, Cain M, Costantini O, Exner DV, Knight BP, Lloyd-Jones D, Kadish AH, Lee B, Moss A, Myerburg R, Olgin J, Passman R, Rosenbaum D, Stevenson W, Zareba W, Zipes DP. Risk stratification for arrhythmic sudden cardiac death: identifying the roadblocks. Circulation. 5. 31. 2011;123:2423-2430. [pmid: 21632516].
24 Lloyd-Jones DM, Hong Y, Labarthe D, Mozaffarian D, Appel LJ, Van Horn L, Greenlund K, et al. Defining and setting national goals for cardiovascular health promotion and disease reduction: the American Heart Association's strategic Impact Goal through 2020 and beyond. Circulation. 2. 2. 2010;121:586-613. [pmid: 20089546].
25 Holmberg M, Holmberg S, Herlitz J. Incidence, duration and survival of ventricular fibrillation in out-of-hospital cardiac arrest patients in sweden. Resuscitation. 2000;44:7-17. [pmid: 10699695].
26 Kuisma M, Suominen P, Korpela R. Paediatric out-of-hospital cardiac arrests--epidemiology and outcome. Resuscitation. 1995;30:141-150. [pmid: 8560103].
27 Steinberger J, Lucas RV Jr., Edwards JE, Titus JL. Causes of sudden unexpected cardiac death in the first two decades of life. Am.J Cardiol. 5. 1. 1996;77:992-995. [pmid: 8644651].
28 Wren C, O'Sullivan JJ, Wright C. Sudden death in children and adolescents. Heart. 2000;83:410-413. [pmid: 10722539].
29 Solomon SD, Zelenkofske S, McMurray JJ, Finn PV, Velazquez E, Ertl G, Harsanyi A, Rouleau JL, Maggioni A, Kober L, White H, Van de Werf F, Pieper K, Califf RM, Pfeffer MA, Valsartan in Acute Myocardial Infarction Trial (VALIANT) Investigators. Sudden death in patients with myocardial infarction and left ventricular dysfunction, heart failure, or both. [Erratum appears in N Engl J Med. 2005 Aug 18;353(7):744]. New England Journal of Medicine. 6. 23. 2005;352:2581-2588. [pmid: 15972864].
30 Hallstrom AP, Cobb LA, Ray R. Smoking as a risk factor for recurrence of sudden cardiac arrest. N.Engl.J Med. 1. 30. 1986;314:271-275. [pmid: 3941718].
31 Cupples LA, Gagnon DR, Kannel WB. Long- and short-term risk of sudden coronary death. Circulation. 1992;85. Suppl-8. [pmid: 1370216].
32 Jouven X, Zureik M, Desnos M, Guerot C, Ducimetiere P. Resting heart rate as a predictive risk factor for sudden death in middle-aged men. Cardiovasc Res. 2001;50:373-378. [pmid: 11334841].
33 Teodorescu C, Reinier K, Uy-Evanado A, Navarro J, Mariani R, Gunson K, Jui J, Chugh SS. Prolonged QRS duration on the resting ECG is associated with sudden death risk in coronary disease, independent of prolonged ventricular repolarization. Heart Rhythm. 2011;8:1562-1567. [pmid: 21699869].
34 Morin DP, Oikarinen L, Viitasalo M, Toivonen L, Nieminen MS, Kjeldsen SE, Dahlof B, John M, Devereux RB, Okin PM. QRS duration predicts sudden cardiac death in hypertensive patients undergoing intensive medical therapy: the LIFE study. Eur Heart J. 2009;30:2908-2914. [pmid: 19687165].
35 Algra A, Tijssen JG, Roelandt JR, Pool J, Lubsen J. QTc prolongation measured by standard 12-lead electrocardiography is an independent risk factor for sudden death due to cardiac arrest. Circulation. 1991;83:1888-1894. [pmid: 2040041].
36 Straus SM, Kors JA, De Bruin ML, van der Hooft CS, Hofman A, Heeringa J, Deckers JW, Kingma JH, Sturkenboom MC, Stricker BH, Witteman JC. Prolonged QTc interval and risk of sudden cardiac death in a population of older adults. J Am Coll Cardiol. 1. 17. 2006;47:362-367. [pmid: 16412861].
37 Passman R, Goldberger JJ. Predicting the future: risk stratification for sudden cardiac death in patients with left ventricular dysfunction. Circulation. 6. 19. 2012;125:3031-3037. [pmid: 22711668].
38 Stecker EC, Vickers C, Waltz J, Socoteanu C, John BT, Mariani R, McAnulty JH, Gunson K, Jui J, Chugh SS. Population-based analysis of sudden cardiac death with and without left ventricular systolic dysfunction: two-year findings from the Oregon Sudden Unexpected Death Study. J Am.Coll.Cardiol. 3. 21. 2006;47:1161-1166. [pmid: 16545646].
39 Atwater BD, Thompson VP, Vest RN III, Shaw LK, Mazzei WR Jr., Al-Khatib SM, Hranitzky PM, Bahnson TD, Velazquez EJ, Califf RM, Lee KL, Roe MT. Usefulness of the Duke Sudden Cardiac Death risk score for predicting sudden cardiac death in patients with angiographic (>75% narrowing) coronary artery disease. Am.J Cardiol. 12. 15. 2009;104:1624-1630. [pmid: 19962465].
40 Goldenberg I, Vyas AK, Hall WJ, Moss AJ, Wang H, He H, Zareba W, McNitt S, Andrews ML. Risk stratification for primary implantation of a cardioverter-defibrillator in patients with ischemic left ventricular dysfunction. J Am.Coll.Cardiol. 1. 22. 2008;51:288-296. [pmid: 18206738].
41 Buxton AE, Lee KL, DiCarlo L, Gold MR, Greer GS, Prystowsky EN, O'Toole MF, Tang A, Fisher JD, Coromilas J, Talajic M, Hafley G. Electrophysiologic testing to identify patients with coronary artery disease who are at risk for sudden death. Multicenter Unsustained Tachycardia Trial Investigators. N.Engl.J.Med. 6. 29. 2000;342:1937-1945. [pmid: 10874061].
42 Moss AJ, Hall WJ, Cannom DS, Daubert JP, Higgins SL, Klein H, Levine JH, Saksena S, Waldo AL, Wilber D, Brown MW, Heo M. Improved survival with an implanted defibrillator in patients with coronary disease at high risk for ventricular arrhythmia. Multicenter Automatic Defibrillator Implantation Trial Investigators. N.Engl.J.Med. 12. 26. 1996;335:1933-1940. [pmid: 8960472].
43 Adabag AS, Therneau TM, Gersh BJ, Weston SA, Roger VL. Sudden death after myocardial infarction. JAMA. 11. 5. 2008;300:2022-2029. [pmid: 18984889].
44 Preliminary report: effect of encainide and flecainide on mortality in a randomized trial of arrhythmia suppression after myocardial infarction. The Cardiac Arrhythmia Suppression Trial (CAST) Investigators. New England Journal of Medicine. 8. 10. 1989;321:406-412. [pmid: 2473403].
45 Effect of the antiarrhythmic agent moricizine on survival after myocardial infarction. The Cardiac Arrhythmia Suppression Trial II Investigators. New England Journal of Medicine. 7. 23. 1992;327:227-233. [pmid: 1377359].
46 Waldo AL, Camm AJ, deRuyter H, Friedman PL, MacNeil DJ, Pauls JF, Pitt B, Pratt CM, Schwartz PJ, Veltri EP. Effect of d-sotalol on mortality in patients with left ventricular dysfunction after recent and remote myocardial infarction. The SWORD Investigators. Survival With Oral d-Sotalol. [Erratum appears in Lancet 1996 Aug 10;348(9024):416]. Lancet. 7. 6. 1996;348:7-12. [pmid: 8691967].
47 Christiansen CB, Torp-Pedersen C, Kober L. Impact of dronedarone in atrial fibrillation and flutter on stroke reduction. Clin Interv Aging. 2010;5:63-69. [pmid: 20396635].
48 Camm AJ, Julian D, Janse G, Munoz A, Schwartz P, Simon P, Frangin G. The European Myocardial Infarct Amiodarone Trial (EMIAT). EMIAT Investigators. Am J Cardiol. 11. 26. 1993;72:95F-98F. [pmid: 8517437].
49 Kuck KH, Cappato R, Siebels J, Ruppel R. Randomized comparison of antiarrhythmic drug therapy with implantable defibrillators in patients resuscitated from cardiac arrest : the Cardiac Arrest Study Hamburg (CASH). Circulation. 8. 15. 2000;102:748-754. [pmid: 10942742].
50 Causes of death in the Antiarrhythmics Versus Implantable Defibrillators (AVID) Trial. J Am Coll Cardiol. 11. 1. 1999;34:1552-1559. [pmid: 10551706].
51 Bardy GH, Lee KL, Mark DB, Poole JE, Packer DL, Boineau R, Domanski M, Troutman C, Anderson J, Johnson G, McNulty SE, Clapp-Channing N, vidson-Ray LD, Fraulo ES, Fishbein DP, Luceri RM, Ip JH. Amiodarone or an implantable cardioverter-defibrillator for congestive heart failure. N.Engl.J.Med. 1. 20. 2005;352:225-237. [pmid: 15659722].
52 Mirowski M, Reid PR, Mower MM, Watkins L, Gott VL, Schauble JF, Langer A, Heilman MS, Kolenik SA, Fischell RE, Weisfeldt ML. Termination of malignant ventricular arrhythmias with an implanted automatic defibrillator in human beings. New England Journal of Medicine. 8. 7. 1980;303:322-324. [pmid: 6991948].
53 Carroll DL, Hamilton GA. Quality of life in implanted cardioverter defibrillator recipients: the impact of a device shock. Heart Lung. 2005;34:169-178. [pmid: 16015221].
54 Irvine J, Dorian P, Baker B, O'Brien BJ, Roberts R, Gent M, Newman D, Connolly SJ. Quality of life in the Canadian Implantable Defibrillator Study (CIDS). Am Heart J. 2002;144:282-289. [pmid: 12177646].
55 Schron EB, Exner DV, Yao Q, Jenkins LS, Steinberg JS, Cook JR, Kutalek SP, Friedman PL, Bubien RS, Page RL, Powell J. Quality of life in the antiarrhythmics versus implantable defibrillators trial: impact of therapy and influence of adverse symptoms and defibrillator shocks. Circulation. 2. 5. 2002;105:589-594. [pmid: 11827924].
56 Grimm W, Plachta E, Maisch B. Antitachycardia pacing for spontaneous rapid ventricular tachycardia in patients with prophylactic cardioverter-defibrillator therapy. Pacing Clin Electrophysiol. 2006;29:759-764. [pmid: 16884513].
57 Wathen MS, DeGroot PJ, Sweeney MO, Stark AJ, Otterness MF, Adkisson WO, Canby RC, Khalighi K, Machado C, Rubenstein DS, Volosin KJ, PainFREE Rx, I. I. I. Prospective randomized multicenter trial of empirical antitachycardia pacing versus shocks for spontaneous rapid ventricular tachycardia in patients with implantable cardioverter-defibrillators: Pacing Fast Ventricular Tachycardia Reduces Shock Therapies (PainFREE Rx II) trial results. Circulation. 10. 26. 2004;110:2591-2596. [pmid: 15492306].
58 Wilkoff BL, Ousdigian KT, Sterns LD, Wang ZJ, Wilson RD, Morgan JM, EMPIRIC, Trial, I. A comparison of empiric to physician-tailored programming of implantable cardioverter-defibrillators: results from the prospective randomized multicenter EMPIRIC trial. J Am Coll Cardiol. 7. 18. 2006;48:330-339. [pmid: 16843184].
59 Wilkoff BL, Williamson BD, Stern RS, Moore SL, Lu F, Lee SW, Birgersdotter-Green UM, Wathen MS, Van Gelder IC, Heubner BM, Brown ML, Holloman KK, PREPARE, Study, I. Strategic programming of detection and therapy parameters in implantable cardioverter-defibrillators reduces shocks in primary prevention patients: results from the PREPARE (Primary Prevention Parameters Evaluation) study. J Am Coll Cardiol. 8. 12. 2008;52:541-550. [pmid: 18687248].
60 Moss AJ, Schuger C, Beck CA, Brown MW, Cannom DS, Daubert JP, Estes NA III, Greenberg H, Hall WJ, Huang DT, Kautzner J, Klein H, McNitt S, Olshansky B, Shoda M, Wilber D, Zareba W. Reduction in Inappropriate Therapy and Mortality through ICD Programming. N.Engl.J.Med. 11. 6. 2012. [pmid: 23131066].
61 Bernard ML, Shotwell M, Nietert PJ, Gold MR. Meta-analysis of bleeding complications associated with cardiac rhythm device implantation. Circ.Arrhythm.Electrophysiol. 6. 1. 2012;5:468-474. [pmid: 22534249].
62 Cheng A, Wang Y, Curtis JP, Varosy PD. Acute lead dislodgements and in-hospital mortality in patients enrolled in the national cardiovascular data registry implantable cardioverter defibrillator registry. J.Am.Coll.Cardiol. 11. 9. 2010;56:1651-1656. [pmid: 21050975].
63 Polin GM, Zado E, Nayak H, Cooper JM, Russo AM, Dixit S, Lin D, Marchlinski FE, Verdino RJ. Proper management of pericardial tamponade as a late complication of implantable cardiac device placement. Am.J Cardiol. 7. 15. 2006;98:223-225. [pmid: 16828597].
64 Sohail MR, Henrikson CA, Braid-Forbes MJ, Forbes KF, Lerner DJ. Mortality and cost associated with cardiovascular implantable electronic device infections. Arch.Intern.Med. 11. 14. 2011;171:1821-1828. [pmid: 21911623].
65 van Rees JB, de Bie MK, Thijssen J, Borleffs CJ, Schalij MJ, van Erven L. Implantation-related complications of implantable cardioverter-defibrillators and cardiac resynchronization therapy devices: a systematic review of randomized clinical trials. J Am.Coll.Cardiol. 8. 30. 2011;58:995-1000. [pmid: 21867832].
66 Curtis JP, Luebbert JJ, Wang Y, Rathore SS, Chen J, Heidenreich PA, Hammill SC, Lampert RI, Krumholz HM. Association of physician certification and outcomes among patients receiving an implantable cardioverter-defibrillator. JAMA. 4. 22. 2009;301:1661-1670. [pmid: 19383957].
67 Freeman JV, Wang Y, Curtis JP, Heidenreich PA, Hlatky MA. Physician procedure volume and complications of cardioverter-defibrillator implantation. Circulation. 1. 3. 2012;125:57-64. [pmid: 22095828].
68 Berdowski J, ten Haaf M, Tijssen JG, Chapman FW, Koster RW. Time in recurrent ventricular fibrillation and survival after out-of-hospital cardiac arrest. Circulation. 9. 14. 2010;122:1101-1108. [pmid: 20805427].
69 Epstein AE, DiMarco JP, Ellenbogen KA, Estes NA III, Freedman RA, Gettes LS, Gillinov AM, et al. ACC/AHA/HRS 2008 Guidelines for Device-Based Therapy of Cardiac Rhythm Abnormalities: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines developed in collaboration with the American Association for Thoracic Surgery and Society of Thoracic Surgeons. [Erratum appears in J Am Coll Cardiol. 2009 Apr 21;53(16):1473], [Erratum appears in J Am Coll Cardiol. 2009 Jan 6;53(1):147]. J Am Coll Cardiol. 5. 27. 2008;51:e1-62. [pmid: 18498951].
70 Gregoratos G, Abrams J, Epstein AE, Freedman RA, Hayes DL, Hlatky MA, Kerber RE, Naccarelli GV, Schoenfeld MH, Silka MJ, Winters SL. ACC/AHA/NASPE 2002 Guideline Update for Implantation of Cardiac Pacemakers and Antiarrhythmia Devices--summary article: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines (ACC/AHA/NASPE Committee to Update the 1998 Pacemaker Guidelines). J Am Coll Cardiol. 11. 6. 2002;40:1703-1719. [pmid: 12427427].
71 Tracy CM, Epstein AE, Darbar D, DiMarco JP, Dunbar SB, Estes NA III, Ferguson TB Jr., Hammill SC, Karasik PE, Link MS, Marine JE, Schoenfeld MH, Shanker AJ, Silka MJ, Stevenson LW, Stevenson WG, Varosy PD. 2012 ACCF/AHA/HRS Focused Update of the 2008 Guidelines for Device-Based Therapy of Cardiac Rhythm Abnormalities: A Report of the American College of Cardiology Foundation/American Heart Association Task Force on Practice Guidelines. J Am Coll Cardiol. 10. 2. 2012;60:1297-1313. [pmid: 22975230].
72 Linde C, Abraham WT, Gold MR, St John Sutton M, Ghio S, Daubert C, REVERSE (REsynchronization reVErses Remodeling in Systolic left vEntricular dysfunction) Study Group. Randomized trial of cardiac resynchronization in mildly symptomatic heart failure patients and in asymptomatic patients with left ventricular dysfunction and previous heart failure symptoms. J Am Coll Cardiol. 12. 2. 2008;52:1834-1843. [pmid: 19038680].
73 Moss Arthur J, Hall W Jackson, Cannom David S, Klein Helmut, Brown Mary W, Daubert James P, Estes NAM, Foster Elyse, Greenberg Henry, Higgins Steven L, Pfeffer Marc A, Solomon Scott D, Wilber David, Zareba Wojciech. Cardiac-Resynchronization Therapy for the Prevention of Heart-Failure Events. New England Journal of Medicine. 10. 1. 2009;361:1329-1338. [pmid: 19723701].
74 Tang AS, Wells GA, Talajic M, Arnold MO, Sheldon R, Connolly S, Hohnloser SH, Nichol G, Birnie DH, Sapp JL, Yee R, Healey JS, Rouleau JL, Resynchronization-Defibrillation for Ambulatory Heart Failure Trial Investigators. Cardiac-resynchronization therapy for mild-to-moderate heart failure. New England Journal of Medicine. 12. 16. 2010;363:2385-2395. [pmid: 21073365].
75 Russo AM, Stainback RF, Bailey SR, Epstein AE, Heidenreich PA, Jessup M, Kapa S, Kremers MS, Lindsay BD, Stevenson LW. ACCF/HRS/AHA/ASE/HFSA/SCAI/SCCT/SCMR 2013 appropriate use criteria for implantable cardioverter-defibrillators and cardiac resynchronization therapy: a report of the American College of Cardiology Foundation appropriate use criteria task force, Heart Rhythm Society, American Heart Association, American Society of Echocardiography, Heart Failure Society of America, Society for Cardiovascular Angiography and Interventions, Society of Cardiovascular Computed Tomography, and Society for Cardiovascular Magnetic Resonance. Heart Rhythm. 2013;10:e11-e58. [pmid: 23473952].
76 Moss AJ, Zareba W, Hall WJ, Klein H, Wilber DJ, Cannom DS, Daubert JP, Higgins SL, Brown MW, Andrews ML, Multicenter Automatic Defibrillator Implantation Trial II investigators. Prophylactic implantation of a defibrillator in patients with myocardial infarction and reduced ejection fraction. New England Journal of Medicine. 3. 21. 2002;346:877-883. [pmid: 11907286].
77 Decision Memo for Implantable Defibrillators (CAG-00157R3). http://www.cms.gov/medicare-coverage-database/details/nca-decision-memo.aspx?NCAId=148&NCDId=110&ncdver=3&NcaName=Implantable+Defibrillators&IsPopup=y&bc=AAAAAAAAEAAA&. 1/8/13. 2005.
78 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ. 2011. AHRQ Publication No. 10(11)-EHC063-EF.:http://www.effectivehealthcare.ahrq.gov/ehc/products/60/318/MethodsGuide_Prepublication_Draft_20110824.pdf.
79 Hammill SC, Kremers MS, Kadish AH, Stevenson LW, Heidenreich PA, Lindsay BD, Mirro MJ, Radford MJ, McKay C, Wang Y, Lang CM, Pontzer K, Rumsfeld J, Phurrough SE, Curtis JP, Brindis RG. Review of the ICD Registry's third year, expansion to include lead data and pediatric ICD procedures, and role for measuring performance. Heart Rhythm. 2009;6:1397-1401. [pmid: 19716099].
80 Wallace BC, Trikalinos TA, Lau J, Brodley C, Schmid CH. Semi-automated screening of biomedical citations for systematic reviews. BMC Bioinform. 2010;11:55. [pmid: 20102628].
81 Lau J. Proposed Governance and Data Management Policy for the Systematic Review Data Repository. Agency for Healthcare Research and Quality. 2012.
82 Higgins JP. Cochrane handbook for systematic reviews of interventions. Version 5.0.2. [updated September 2009]. The Cochrane Collaboration. 2009.
83 Chou R, Aronson N, Atkins D, Ismaila AS, Santaguida P, Smith DH, Whitlock E, Wilt TJ, Moher D. AHRQ series paper 4: assessing harms when comparing medical interventions: AHRQ and the effective health-care program. J.Clin.Epidemiol. 2010;63:502-512. [pmid: 18823754].
84 Santaguida P, Raina P, Ismaila A. McMaster Quality Assessment Scale of Harms (McHarm) for primary studies. http://bmg.cochrane.org/sites/bmg.cochrane.org/files/uploads/McHarm%20for%20Primary%20Studies.pdf. 1/8/13.
85 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin.Trials. 1986;7:177-188. [pmid: 3802833].
86 Tierney JF, Stewart LA, Ghersi D, Burdett S, Sydes MR. Practical methods for incorporating summary time-to-event data into meta-analysis. Trials. 2007;8:16. PMID:. [pmid: 17555582].
87 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat.Med. 6. 15. 2002;21:1539-1558. [pmid: 12111919].
88 Higgins JP, Thompson SG, Deeks JJ, Altman DG. Measuring inconsistency in meta-analyses. BMJ. 9. 6. 2003;327:557-560. [pmid: 12958120].
89 Altman DG, Andersen PK. Calculating the number needed to treat for trials where the outcome is time to an event. BMJ. 12. 4. 1999;319:1492-1495. [pmid: 10582940].
90 Owens DK, Lohr KN, Atkins D, Treadwell JR, Reston JT, Bass EB, Chang S, Helfand M. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. Journal of Clinical Epidemiology. 2010;63:513-523. [pmid: 19595577].
91 Bansch D, Antz M, Boczor S, Volkmer M, Tebbenjohanns J, Seidl K, Block M, Gietzen F, Berger J, Kuck KH. Primary prevention of sudden cardiac death in idiopathic dilated cardiomyopathy: the Cardiomyopathy Trial (CAT). Circulation. 3. 26. 2002;105:1453-1458. [pmid: 11914254].
92 Barsheshet A, Moss AJ, McNitt S, Jons C, Glikson M, Klein HU, Huang DT, Steinberg JS, Brown MW, Zareba W, Goldenberg I. Long-term implications of cumulative right ventricular pacing among patients with an implantable cardioverter-defibrillator. Heart Rhythm. 2011;8:212-218. [pmid: 21044897].
93 Berenbom LD, Weiford BC, Vacek JL, Emert MP, Hall WJ, Andrews ML, McNitt S, Zareba W, Moss AJ. Differences in outcomes between patients treated with single- versus dual-chamber implantable cardioverter defibrillators: a substudy of the Multicenter Automatic Defibrillator Implantation Trial II. Ann.Noninvasive.Electrocardiol. 2005;10:429-435. [pmid: 16255753].
94 Bigger JT Jr. Prophylactic use of implanted cardiac defibrillators in patients at high risk for ventricular arrhythmias after coronary-artery bypass graft surgery. Coronary Artery Bypass Graft (CABG) Patch Trial Investigators. N.Engl.J.Med. 11. 27. 1997;337:1569-1575. [pmid: 9371853].
95 Bristow MR, Saxon LA, Boehmer J, Krueger S, Kass DA, De Marco T, Carson P, DiCarlo L, DeMets D, White BG, DeVries DW, Feldman AM. Cardiac-resynchronization therapy with or without an implantable defibrillator in advanced chronic heart failure. N.Engl.J.Med. 5. 20. 2004;350:2140-2150. [pmid: 15152059].
96 Goldenberg I, Moss AJ, McNitt S, Zareba W, Hall WJ, Andrews ML, Wilber DJ, Klein HU. Time dependence of defibrillator benefit after coronary revascularization in the Multicenter Automatic Defibrillator Implantation Trial (MADIT)-II. J.Am.Coll.Cardiol. 5. 2. 2006;47:1811-1817. [pmid: 16682305].
97 Goldenberg I, Moss AJ, McNitt S, Zareba W, Andrews ML, Hall WJ, Greenberg H, Case RB. Relations among renal function, risk of sudden cardiac death, and benefit of the implanted cardiac defibrillator in patients with ischemic left ventricular dysfunction. Am.J.Cardiol. 8. 15. 2006;98:485-490. [pmid: 16893702].
98 Hohnloser SH, Kuck KH, Dorian P, Roberts RS, Hampton JR, Hatala R, Fain E, Gent M, Connolly SJ. Prophylactic use of an implantable cardioverter-defibrillator after acute myocardial infarction. N.Engl.J.Med. 12. 9. 2004;351:2481-2488. [pmid: 15590950].
99 Kadish A, Dyer A, Daubert JP, Quigg R, Estes NA, Anderson KP, Calkins H, Hoch D, Goldberger J, Shalaby A, Sanders WE, Schaechter A, Levine JH. Prophylactic defibrillator implantation in patients with nonischemic dilated cardiomyopathy. N.Engl.J.Med. 5. 20. 2004;350:2151-2158. [pmid: 15152060].
100 Namerow PB, Firth BR, Heywood GM, Windle JR, Parides MK. Quality-of-life six months after CABG surgery in patients randomized to ICD versus no ICD therapy: findings from the CABG Patch Trial. Pacing Clin.Electrophysiol. 1999;22:1305-1313. [pmid: 10527011].
101 Noyes K, Corona E, Zwanziger J, Hall WJ, Zhao H, Wang H, Moss AJ, Dick AW. Health-related quality of life consequences of implantable cardioverter defibrillators: results from MADIT II. Med.Care. 2007;45:377-385. [pmid: 17446823].
102 Steinbeck G, Andresen D, Seidl K, Brachmann J, Hoffmann E, Wojciechowski D, Kornacewicz-Jach Z, Sredniawa B, Lupkovics G, Hofgartner F, Lubinski A, Rosenqvist M, Habets A, Wegscheider K, Senges J. Defibrillator implantation early after myocardial infarction. N.Engl.J.Med. 10. 8. 2009;361:1427-1436. [pmid: 19812399].
103 Strickberger SA, Hummel JD, Bartlett TG, Frumin HI, Schuger CD, Beau SL, Bitar C, Morady F. Amiodarone versus implantable cardioverter-defibrillator:randomized trial in patients with nonischemic dilated cardiomyopathy and asymptomatic nonsustained ventricular tachycardia--AMIOVIRT. J.Am.Coll.Cardiol. 5. 21. 2003;41:1707-1712. [pmid: 12767651].
104 Wilber DJ, Zareba W, Hall WJ, Brown MW, Lin AC, Andrews ML, Burke M, Moss AJ. Time dependence of mortality risk and defibrillator benefit after myocardial infarction. Circulation. 3. 9. 2004;109:1082-1084. [pmid: 14993128].
105 Chan PS, Nallamothu BK, Spertus JA, Masoudi FA, Bartone C, Kereiakes DJ, Chow T. Impact of age and medical comorbidity on the effectiveness of implantable cardioverter-defibrillators for primary prevention. Circ.Cardiovasc.Qual.Outcomes. 2009;2:16-24. [pmid: 20031808].
106 Fonarow GC, Feliciano Z, Boyle NG, Knight L, Woo MA, Moriguchi JD, Laks H, Wiener I. Improved survival in patients with nonischemic advanced heart failure and syncope treated with an implantable cardioverter-defibrillator. Am.J.Cardiol. 4. 15. 2000;85:981-985. [pmid: 10760339].
107 Hernandez AF, Fonarow GC, Hammill BG, Al-Khatib SM, Yancy CW, O'Connor CM, Schulman KA, Peterson ED, Curtis LH. Clinical effectiveness of implantable cardioverter-defibrillators among medicare beneficiaries with heart failure. Circ.Heart Fail. 2010;3:7-13. [pmid: 20009044].
108 Mezu U, Adelstein E, Jain S, Saba S. Effectiveness of implantable defibrillators in octogenarians and nonagenarians for primary prevention of sudden cardiac death. Am.J.Cardiol. 9. 1. 2011;108:718-722. [pmid: 21640321].
109 Al-Khatib SM, Hellkamp AS, Lee KL, Anderson J, Poole JE, Mark DB, Bardy GH. Implantable cardioverter defibrillator therapy in patients with prior coronary revascularization in the Sudden Cardiac Death in Heart Failure Trial (SCD-HeFT). J.Cardiovasc.Electrophysiol. 2008;19:1059-1065. [pmid: 18479330].
110 Piccini JP, Al-Khatib SM, Hellkamp AS, Anstrom KJ, Poole JE, Mark DB, Lee KL, Bardy GH. Mortality benefits from implantable cardioverter-defibrillator therapy are not restricted to patients with remote myocardial infarction: an analysis from the Sudden Cardiac Death in Heart Failure Trial (SCD-HeFT). Heart Rhythm. 2011;8:393-400. [pmid: 21109025].
111 Chung ES, Dan D, Solomon SD, Bank AJ, Pastore J, Iyer A, Berger RD, Franklin JO, Jones G, Machado C, Stolen CM. Effect of peri-infarct pacing early after myocardial infarction: results of the prevention of myocardial enlargement and dilatation post myocardial infarction study. Circ.Heart Fail. 2010;3:650-658. [pmid: 20852059].
112 Diab IG, Hunter RJ, Kamdar R, Berriman T, Duncan E, Richmond L, Baker V, Abrams D, Earley MJ, Sporton S, Schilling RJ. Does ventricular dyssynchrony on echocardiography predict response to cardiac resynchronisation therapy? A randomised controlled study. Heart. 2011;97:1410-1416. [pmid: 21700757].
113 Barsheshet A, Goldenberg I, Narins CR, Moss AJ, McNitt S, Wang PJ, Huang DT, Hall WJ, Zareba W, Eldar M, Guetta V. Time dependence of life-threatening ventricular tachyarrhythmias after coronary revascularization in MADIT-CRT. Heart Rhythm. 2010;7:1421-1427. [pmid: 20620231].
114 Aggarwal A, Wang Y, Rumsfeld JS, Curtis JP, Heidenreich PA. Clinical characteristics and in-hospital outcome of patients with end-stage renal disease on dialysis referred for implantable cardioverter-defibrillator implantation. Heart Rhythm. 2009;6:1565-1571. [pmid: 19879533].
115 Dewland TA, Pellegrini CN, Wang Y, Marcus GM, Keung E, Varosy PD. Dual-chamber implantable cardioverter-defibrillator selection is associated with increased complication rates and mortality among patients enrolled in the NCDR implantable cardioverter-defibrillator registry. J.Am.Coll.Cardiol. 8. 30. 2011;58:1007-1013. [pmid: 21867834].
116 Freeman JV, Wang Y, Curtis JP, Heidenreich PA, Hlatky MA. The relation between hospital procedure volume and complications of cardioverter-defibrillator implantation from the implantable cardioverter-defibrillator registry. J.Am.Coll.Cardiol. 9. 28. 2010;56:1133-1139. [pmid: 20863954].
117 Haines DE, Wang Y, Curtis J. Implantable cardioverter-defibrillator registry risk score models for acute procedural complications or death after implantable cardioverter-defibrillator implantation. Circulation. 5. 17. 2011;123:2069-2076. [pmid: 21537001].
118 Peterson PN, Daugherty SL, Wang Y, Vidaillet HJ, Heidenreich PA, Curtis JP, Masoudi FA. Gender differences in procedure-related adverse events in patients receiving implantable cardioverter-defibrillator therapy. Circulation. 3. 3. 2009;119:1078-1084. [pmid: 19221223].
119 Tsai V, Goldstein MK, Hsia HH, Wang Y, Curtis J, Heidenreich PA. Age differences in primary prevention implantable cardioverter-defibrillator use in U.S. individuals. J Am Geriatr Soc. 2011;59:1589-1595. [pmid: 21883101].
120 Tsai V, Goldstein MK, Hsia HH, Wang Y, Curtis J, Heidenreich PA. Influence of age on perioperative complications among patients undergoing implantable cardioverter-defibrillators for primary prevention in the United States. Circ Cardiovasc Qual Outcomes. 2011;4:549-556. [pmid: 21878667].
121 Wei S, Loyo-Berrios NI, Haigney MC, Cheng H, Pinnow EE, Mitchell KR, Beachy JH, Woodward AM, Wang Y, Curtis JP, Marinac-Dabic D. Elevated B-type natriuretic peptide is associated with increased in-hospital mortality or cardiac arrest in patients undergoing implantable cardioverter-defibrillator implantation. Circ.Cardiovasc.Qual.Outcomes. 2011;4:346-354. [pmid: 21487093].
122 Sticherling C, Zabel M, Spencker S, Meyerfeldt U, Eckardt L, Behrens S, Niehaus M, ADRIA, Investigators. Comparison of a novel, single-lead atrial sensing system with a dual-chamber implantable cardioverter-defibrillator system in patients without antibradycardia pacing indications: results of a randomized study. Circ Arrhythm Electrophysiol. 2011;4:56-63. [pmid: 21156772].
123 Birnie DH, Parkash R, Exner DV, Essebag V, Healey JS, Verma A, Coutu B, Kus T, Mangat I, Ayala-Paredes F, Nery P, Wells G, Krahn AD. Clinical predictors of Fidelis lead failure: report from the Canadian Heart Rhythm Society Device Committee. Circulation. 3. 13. 2012;125:1217-1225. [pmid: 22311781].
124 Borleffs CJ, van Erven L, van Bommel RJ, van der Velde ET, van der Wall EE, Bax JJ, Rosendaal FR, Schalij MJ. Risk of failure of transvenous implantable cardioverter-defibrillator leads. Circ Arrhythm Electrophysiol. 2009;2:411-416. [pmid: 19808497].
125 Brullmann S, Dichtl W, Paoli U, Haegeli L, Schmied C, Steffel J, Brunckhorst C, Hintringer F, Seifert B, Duru F, Wolber T. Comparison of benefit and mortality of implantable cardioverter-defibrillator therapy in patients aged >=75 years versus those <75 years. Am J Cardiol. 3. 1. 2012;109:712-717. [pmid: 22154315].
126 Brumberg GE, Kaseer B, Shah H, Saba S, Jain S. Biventricular defibrillator patients have higher complication rates after revision of recalled leads. Pacing Clin Electrophysiol. 2012;35:665-671. [pmid: 22519559].
127 Charytan DM, Patrick AR, Liu J, Setoguchi S, Herzog CA, Brookhart MA, Winkelmayer WC. Trends in the use and outcomes of implantable cardioverter-defibrillators in patients undergoing dialysis in the United States. Am J Kidney Dis. 2011;58:409-417. [pmid: 21664735].
128 de Bie MK, van Rees JB, Thijssen J, Borleffs CJ, Trines SA, Cannegieter SC, Schalij MJ, van Erven L. Cardiac device infections are associated with a significant mortality risk. Heart Rhythm. 2012;9:494-498. [pmid: 22056722].
129 Dichtl W, Wolber T, Paoli U, Brullmann S, Stuhlinger M, Berger T, Spuller K, Strasak A, Pachinger O, Haegeli LM, Duru F, Hintringer F. Appropriate therapy but not inappropriate shocks predict survival in implantable cardioverter defibrillator patients. Clin Cardiol. 2011;34:433-436. [pmid: 21678454].
130 Gradaus R, Block M, Brachmann J, Breithardt G, Huber HG, Jung W, Kranig W, Mletzko RU, Schoels W, Seidl K, Senges J, Siebels J, Steinbeck G, Stellbrink C, Andresen D, German, EURID Registry. Mortality, morbidity, and complications in 3344 patients with implantable cardioverter defibrillators: results fron the German ICD Registry EURID. Pacing Clin Electrophysiol. 2003;26. t-8. [pmid: 12914630].
131 Hauser RG, Mugglin AS, Friedman PA, Kramer DB, Kallinen L, McGriff D, Hayes DL. Early detection of an underperforming implantable cardiovascular device using an automated safety surveillance tool. Circ Cardiovasc Qual Outcomes. 3. 1. 2012;5:189-196. [pmid: 22396584].
132 Landolina M, Gasparini M, Lunati M, Iacopino S, Boriani G, Bonanno C, Vado A, Proclemer A, Capucci A, Zucchiatti C, Valsecchi S, Ricci RP, Santini M, Cardiovascular Centers Participating in the ClinicalService Project. Long-term complications related to biventricular defibrillator implantation: rate of surgical revisions and impact on survival: insights from the Italian Clinical Service Database. Circulation. 6. 7. 2011;123:2526-2535. [pmid: 21576653].
133 Lee DS, Krahn AD, Healey JS, Birnie D, Crystal E, Dorian P, Simpson CS, Khaykin Y, Cameron D, Janmohamed A, Yee R, Austin PC, Chen Z, Hardy J, Tu JV. Investigators of the Ontario ICD Database. Evaluation of early complications related to De Novo cardioverter defibrillator implantation insights from the Ontario ICD database. J Am Coll Cardiol. 2. 23. 2010;55:774-782. [pmid: 20170816].
134 Lyman S, Sedrakyan A, Do H, Razzano R, Mushlin AI. Infrequent physician use of implantable cardioverter-defibrillators risks patient safety. Heart. 2011;97:1655-1660. [pmid: 21795298].
135 MacFadden DR, Crystal E, Krahn AD, Mangat I, Healey JS, Dorian P, Birnie D, Simpson CS, Khaykin Y, Pinter A, Nanthakumar K, Calzavara AJ, Austin PC, Tu JV, Lee DS. Sex differences in implantable cardioverter-defibrillator outcomes: findings from a prospective defibrillator database. Ann Intern Med. 2. 7. 2012;156:195-203. [pmid: 22312139].
136 Morrison TB, Friedman PA, Kallinen LM, Hodge DO, Crusan D, Kumar K, Hayes DL, Rea RF, Hauser RG. Impact of implanted recalled sprint Fidelis lead on patient mortality. J Am Coll Cardiol. 7. 12. 2011;58:278-283. [pmid: 21737019].
137 Porterfield JG, Porterfield LM, Kuck KH, Corbisiero R, Greenberg SM, Hindricks G, Wazni O, Beau SL, Herre JM. Clinical performance of the St. Jude Medical Riata defibrillation lead in a large patient population. J Cardiovasc Electrophysiol. 2010;21:551-556. [pmid: 19925609].
138 Remmelts HH, Meine M, Loh P, Hauer R, Doevendans PA, van Herwerden LA, Hopmans TE, Ellerbroek PM. Infection after ICD implantation: operating room versus cardiac catheterisation laboratory. Neth Heart J. 2009;17:95-100. [pmid: 19325900].
139 Thijssen J, Borleffs CJ, van Rees JB, Man S, de Bie MK, Venlet J, van der Velde ET, van Erven L, Schalij MJ. Implantable cardioverter-defibrillator longevity under clinical circumstances: an analysis according to device type, generation, and manufacturer. Heart Rhythm. 2012;9:513-519. [pmid: 22094073].
140 Tsai FS, Aronow WS, Devabhaktuni S, Desai H, Kruger A, Lai HM, Frishman WH, Cohen M, Sorbera C. Prevalence of complications during implantation and during 38-month follow-up of 1060 consecutive patients with implantable cardioverter-defibrillators. Am J Ther. 2010;17:e8-10. [pmid: 19262366].
141 van Rees JB, van Welsenes GH, Borleffs CJ, Thijssen J, van der Velde ET, van der Wall EE, van Erven L, Schalij MJ. Update on small-diameter implantable cardioverter-defibrillator leads performance. Pacing Clin Electrophysiol. 2012;35:652-658. [pmid: 22352338].
142 Varma N, Michalski J, Epstein AE, Schweikert R. Automatic remote monitoring of implantable cardioverter-defibrillator lead and generator performance: the Lumos-T Safely RedUceS RouTine Office Device Follow-Up (TRUST) trial. Circ Arrhythm Electrophysiol. 10. 1. 2010;3:428-436. [pmid: 20716717].
143 Bode F, Himmel F, Reppel M, Mortensen K, Schunkert H, Wiegand UK. Should all dysfunctional high-voltage leads be extracted? Results of a single-centre long-term registry. Europace. 2012;14:1764-1770. [pmid: 22753865].
144 Cheung JW, Tobin-Hess A, Patel A, Slotwiner DJ, Goldner BG. Trends in Fidelis lead survival: transition from an exponential to linear pattern of lead failure over time. Circ.Arrhythm.Electrophysiol. 2012;5:906-912. [pmid: 22923271].
145 Freudenberger RS, Hellkamp AS, Halperin JL, Poole J, Anderson J, Johnson G, Mark DB, Lee KL, Bardy GH. Risk of thromboembolism in heart failure: an analysis from the Sudden Cardiac Death in Heart Failure Trial (SCD-HeFT). Circulation. 5. 22. 2007;115:2637-2641. [pmid: 17485579].
146 Sengupta J, Kendig AC, Goormastic M, Hwang ES, Ching EA, Chung R, Lindsay BD, Tchou PJ, Wilkoff BL, Niebauer MJ, Martin DO, Varma N, Wazni O, Saliba W, Kanj M, Bhargava M, Dresing T, Taigen T, Ingelmo C, Bassiouny M, Cronin EM, Wilsmore B, Rickard J, Chung MK. Implantable cardioverter-defibrillator FDA safety advisories: Impact on patient mortality and morbidity. Heart Rhythm. 2012;9:1619-1626. [pmid: 22772136].
147 Tzogias L, Bellavia D, Sharma S, Donohue TJ, Schoenfeld MH. Natural history of the Sprint Fidelis lead: survival analysis from a large single-center study. J.Interv.Card Electrophysiol. 2012;34:37-44. [pmid: 22314669].
148 Position of the Swiss Nursing Association to the report on “Home nursing from the viewpoint of the social insurances” Formulate the aims positively. Krankenpfl.Soins.Infirm. 1992;85:74-75. [pmid: 1597965].
149 Parkash R, Thibault B, Sterns L, Sapp J, Krahn A, Talajic M, Luce M, Yetisir E, Theoret-Patrick P, Wells G, Tang A. Sprint Fidelis lead fractures in patients with cardiac resynchronization therapy devices: insight from the Resynchronization/Defibrillation for Ambulatory Heart Failure (RAFT) study. Circulation. 12. 18. 2012;126:2928-2934. [pmid: 23159551].
150 Martin DT, McNitt S, Nesto RW, Rutter MK, Moss AJ. Cardiac resynchronization therapy reduces the risk of cardiac events in patients with diabetes enrolled in the multicenter automatic defibrillator implantation trial with cardiac resynchronization therapy (MADIT-CRT). Circ Heart Fail. 2011;4:332-338. [pmid: 21350054].
151 van Rees JB, Borleffs CJ, Thijssen J, de Bie MK, van Erven L, Cannegieter SC, Bax JJ, Schalij MJ. Prophylactic implantable cardioverter-defibrillator treatment in the elderly: therapy, adverse events, and survival gain. Europace. 2012;14:66-73. [pmid: 21920909].
152 Desai H, Aronow WS, Ahn C, Gandhi K, Hussain S, Lai HM, Sharma M, Frishman WH, Cohen M, Sorbera C. Risk factors for appropriate cardioverter-defibrillator shocks, inappropriate cardioverter-defibrillator shocks, and time to mortality in 549 patients with heart failure. Am J Cardiol. 5. 1. 2010;105:1336-1338. [pmid: 20403488].
153 Kleemann T, Hochadel M, Strauss M, Skarlos A, Seidl K, Zahn R. Comparison Between Atrial Fibrillation-Triggered Implantable Cardioverter-Defibrillator (ICD) Shocks and Inappropriate Shocks Caused by Lead Failure: Different Impact on Prognosis in Clinical Practice. J Cardiovasc Electrophysiol. 2012;23:735-740. [pmid: 22313314].
154 Larsen PD, De Silva P, Harding SA, Woodcock E, Lever NA. Use of implantable cardioverter defibrillators in the New Zealand context from 2000 to 2007. N Z Med J. 2. 19. 2010;123:76-85. [pmid: 20186244].
155 Sandesara CM, Sullivan RM, Russo AM, Li W, Kendig A, Day JD, Mullin C, Stolen K, Olshansky B. Older persons with diabetes receive fewer inappropriate ICD shocks: results from the INTRINSIC RV trial. J Cardiovasc Transl Res. 2011;4:27-34. [pmid: 21086086].
156 Saxon LA, Hayes DL, Gilliam FR, Heidenreich PA, Day J, Seth M, Meyer TE, Jones PW, Boehmer JP. Long-term outcome after ICD and CRT implantation and influence of remote device follow-up: the ALTITUDE survival study. Circulation. 12. 7. 2010;122:2359-2367. [pmid: 21098452].
157 Schaer B, Sticherling C, Szili-Torok T, Osswald S, Jordaens L, Theuns DA. Impact of left ventricular ejection fraction on occurrence of ventricular events in defibrillator patients with coronary artery disease. Europace. 2011;13:1562-1567. [pmid: 21712284].
158 Sweeney MO, Sherfesee L, DeGroot PJ, Wathen MS, Wilkoff BL. Differences in effects of electrical therapy type for ventricular arrhythmias on mortality in implantable cardioverter-defibrillator patients. Heart Rhythm. 2010;7:353-360. [pmid: 20185109].
159 van Welsenes GH, van Rees JB, Borleffs CJ, Cannegieter SC, Bax JJ, van Erven L, Schalij MJ. Long-term follow-up of primary and secondary prevention implantable cardioverter defibrillator patients. Europace. 2011;13:389-394. [pmid: 21208947].
160 Gold MR, Ahmad S, Browne K, Berg KC, Thackeray L, Berger RD. Prospective comparison of discrimination algorithms to prevent inappropriate ICD therapy: primary results of the Rhythm ID Going Head to Head Trial. Heart Rhythm. 2012;9:370-377. [pmid: 21978966].
161 Sweeney MO, Sakaguchi S, Simons G, Machado C, Connett JE, Yang F, OMNI, Study, I. Response to the Center for Medicare & Medicaid Services coverage with evidence development request for primary prevention implantable cardioverter-defibrillators: Data from the OMNI study. Heart Rhythm. 2012;9:1058-1066. [pmid: 22387371].
162 van Rees JB, Borleffs CJ, de Bie MK, Stijnen T, van Erven L, Bax JJ, Schalij MJ. Inappropriate implantable cardioverter-defibrillator shocks: incidence, predictors, and impact on mortality. J Am Coll Cardiol. 2. 1. 2011;57:556-562. [pmid: 21272746].
163 Bigger JT Jr., Whang W, Rottman JN, Kleiger RE, Gottlieb CD, Namerow PB, Steinman RC, Estes NA III. Mechanisms of death in the CABG Patch trial: a randomized trial of implantable cardiac defibrillator prophylaxis in patients at high risk of death after coronary artery bypass graft surgery. Circulation. 3. 23. 1999;99:1416-1421. [pmid: 10086963].
164 Ghanbari Hamid, Dalloul Ghassan, Hasan Reema, Daccarett Marcos, Saba Souheil, David Shukri, Machado Christian. Effectiveness of Implantable Cardioverter-Defibrillators for the Primary Prevention of Sudden Cardiac Death in Women With Advanced Heart Failure: A Meta-analysis of Randomized Controlled Trials. Archives of Internal Medicine. 9. 14. 2009;169:1500-1506. [pmid: 19752408].
165 Santangeli P, Pelargonio G, Dello Russo A, Casella M, Bisceglia C, Bartoletti S, Santarelli P, Di Biase L, Natale A. Gender differences in clinical outcome and primary prevention defibrillator benefit in patients with severe left ventricular dysfunction: a systematic review and meta-analysis. Heart Rhythm. 2010;7:876-882. [pmid: 20380893].
166 Buxton AE, Lee KL, Fisher JD, Josephson ME, Prystowsky EN, Hafley G. A randomized study of the prevention of sudden death in patients with coronary artery disease. Multicenter Unsustained Tachycardia Trial Investigators. N.Engl.J.Med. 12. 16. 1999;341:1882-1890. [pmid: 10601507].
167 Moss AJ, Hall WJ, Cannom DS, Klein H, Brown MW, Daubert JP, Estes NA III, Foster E, Greenberg H, Higgins SL, Pfeffer MA, Solomon SD, Wilber D, Zareba W, MADIT-CRT Trial Investigators. Cardiac-resynchronization therapy for the prevention of heart-failure events. New England Journal of Medicine. 10. 1. 2009;361:1329-1338. [pmid: 19723701].
168 Schuger C, Daubert JP, Brown MW, Cannom D, Estes NA III, Hall WJ, Kayser T, Klein H, Olshansky B, Power KA, Wilber D, Zareba W, Moss AJ. Multicenter automatic defibrillator implantation trial: reduce inappropriate therapy (MADIT-RIT): background, rationale, and clinical protocol. Ann Noninvasive Electrocardiol. 2012;17:176-185. [pmid: 22816536].
169 Masoudi FA, Go AS, Magid DJ, Cassidy-Bushrow AE, Doris JM, Fiocchi F, Garcia-Montilla R, Glenn KA, Goldberg RJ, Gupta N, Gurwitz JH, Hammill SC, Hayes JJ, Jackson N, Kadish A, Lauer M, Miller AW, Multerer D, Peterson PN, Reifler LM, Reynolds K, Saczynski JS, Schuger C, Sharma PP, Smith DH, Suits M, Sung SH, Varosy PD, Vidaillet HJ, Greenlee RT. Longitudinal study of implantable cardioverter-defibrillators: methods and clinical characteristics of patients receiving implantable cardioverter-defibrillators for primary prevention in contemporary practice. Circ.Cardiovasc.Qual.Outcomes. 2012;5:e78-e85. [pmid: 23170006].
170 Nanthakumar K, Epstein AE, Kay GN, Plumb VJ, Lee DS. Prophylactic implantable cardioverter-defibrillator therapy in patients with left ventricular systolic dysfunction: a pooled analysis of 10 primary prevention trials. J.Am.Coll.Cardiol. 12. 7. 2004;44:2166-2172. [pmid: 15582314].
171 Desai AS, Fang JC, Maisel WH, Baughman KL. Implantable defibrillators for the prevention of mortality in patients with nonischemic cardiomyopathy: a meta-analysis of randomized controlled trials. JAMA. 12. 15. 2004;292:2874-2879. [pmid: 15598919].
172 Santangeli P, Di Biase L, Dello Russo A, Casella M, Bartoletti S, Santarelli P, Pelargonio G, Natale A. Meta-analysis: age and effectiveness of prophylactic implantable cardioverter-defibrillators. Ann Intern.Med. 11. 2. 2010;153:592-599. [pmid: 21041579].
173 Young JB, Abraham WT, Smith AL, Leon AR, Lieberman R, Wilkoff B, Canby RC, Schroeder JS, Liem LB, Hall S, Wheelan K. Combined cardiac resynchronization and implantable cardioversion defibrillation in advanced chronic heart failure: the MIRACLE ICD Trial. JAMA. 5. 28. 2003;289:2685-2694. [pmid: 12771115].
174 Beshai JF, Grimm RA, Nagueh SF, Baker JH, Beau SL, Greenberg SM, Pires LA, Tchou PJ. Cardiac-resynchronization therapy in heart failure with narrow QRS complexes. N.Engl.J.Med. 12. 13. 2007;357:2461-2471. [pmid: 17986493].
175 Epstein AE, Kay GN, Plumb VJ, McElderry HT, Doppalapudi H, Yamada T, Shafiroff J, Syed ZA, Shkurovich S. Implantable cardioverter-defibrillator prescription in the elderly. Heart Rhythm. 2009;6:1136-1143. [pmid: 19539542].
176 Chen CY, Stevenson LW, Stewart GC, Seeger JD, Williams L, Jalbert JJ, Setoguchi S. Impact of baseline heart failure burden on post-implantable cardioverter-defibrillator mortality among medicare beneficiaries. J Am.Coll.Cardiol. 5. 28. 2013;61:2142-2150. [pmid: 23541973].
177 Costantini O, Hohnloser SH, Kirk MM, Lerman BB, Baker JH, Sethuraman B, Dettmer MM, Rosenbaum DS. The ABCD (Alternans Before Cardioverter Defibrillator) Trial: strategies using T-wave alternans to improve efficiency of sudden cardiac death prevention. J Am.Coll.Cardiol. 2. 10. 2009;53:471-479. [pmid: 19195603].
178 FDA approves first subcutaneous heart defibrillator. http://www.fda.gov/NewsEvents/Newsroom/PressAnnouncements/ucm321755.htm. 1/8/13. 2012.
179 Gasparini M, Proclemer A, Klersy C, Kloppe A, Lunati M, Ferrer JB, Hersi A, Gulaj M, Wijfels MC, Santi E, Manotta L, Arenal A. Effect of long-detection interval vs standard-detection interval for implantable cardioverter-defibrillators on antitachycardia pacing and shock delivery: the ADVANCE III randomized clinical trial. JAMA. 5. 8. 2013;309:1903-1911. [pmid: 23652522].