# Methods

The methods for this Technology Assessment follow the AHRQ Methods Guide for Effectiveness and Comparative Effectiveness Reviews (hereafter referred to as the Methods Guide; available at www.effectivehealthcare.ahrq.gov/methodsguide.cfm).78

## AHRQ Task Order Officer

The AHRQ Task Order Officer (TOO) was responsible for overseeing all aspects of this project. The TOO facilitated a common understanding among all parties involved in the project, resolved ambiguities, and fielded all EPC queries regarding the scope and processes of the project. The TOO and other staff at AHRQ reviewed the report for consistency, clarity, and to ensure that it conforms to AHRQ standards.

## External Expert Input

The Coverage and Analysis Group at the Centers for Medicare and Medicaid Services (CMS) requested this report from The Technology Assessment Program (TAP) at the Agency for Healthcare Research and Quality (AHRQ). AHRQ assigned this report to the Tufts Evidence-based Practice Center: (Contract Number: 290 2007 10055 I).

The Key Questions in this TA were drafted by CMS and refined by the Evidence-based Practice Center (EPC) through discussions with Agency for Healthcare Research and Quality (AHRQ) Task Order Officer and CMS experts

## Key Questions

Key Questions were refined to take into account the patient populations, interventions, comparators, outcomes, and study designs that are clinically relevant for the use of ICDs in the primary prevention of SCD. Three Key Questions are addressed in the present report. Key Question 1 pertains to clinical outcomes (benefits) of ICDs for primary prevention of SCD. Key Question 2 pertains to adverse events associated with ICDs. Key Question 3 pertains to the description of patients enrolled in ICD trials for primary prevention. The Key Questions are listed at the end of the Introduction.

## Analytic Framework

To guide the development of the Key Questions for the evaluation of ICDs, we developed an analytic framework (Figure 1) that maps the specific linkages associating the populations of interest, the interventions, and the outcomes of interest (intermediate outcomes, surrogate outcomes, and clinical outcomes). Specifically, this analytic framework depicts the chain of logic that evidence must support to link the interventions to improved health outcomes.

Figure 1 Analytic framework for the evaluation of ICDs in the primary prevention of SCD

The Key Questions (KQs) are shown within the context of the PICO (Population, Intervention, Comparators, and Outcomes) criteria. The figure illustrates how implantable cardioverter–defibrillator (ICD) implantation for primary prevention of sudden cardiac death affects clinical outcomes and may result in adverse events.

Figure 1 depicts the Key Questions shown within the context of the PICO (Population, Intervention, Comparators, and Outcomes) criteria. The figure illustrates how implantable cardioverter–defibrillator implantation for primary prevention of sudden cardiac death may affect clinical outcomes (all-cause death, sudden cardiac death, ventricular tachyarrhythmia, quality of life, other patient-reported outcomes) and may result in adverse events (early, during hospitalization for ICD implantation; late; inappropriate shock).

## Literature Search and Study Selection

We conducted the literature search in MEDLINE^®^ and the Cochrane Central Register of Controlled Trials with no language restrictions (Appendix A). Key words included terms related to the device of interest (ICDs) and terms related to study design. The first search was performed on November 11, 2011, with a final update on December 4, 2012.

### Key Question 1

For Key Question 1, randomized controlled trials (RCTs) or comparative longitudinal cohort studies (nonrandomized comparative studies [nRCSs]) were eligible if they provided relevant data directly comparing an ICD to no ICD, including antiarrhythmic drug treatment, or to different ICD interventions and if they included at least 10 participants per study group. For nRCSs, only those studies that used concurrent controls and reported a multivariate analysis were included. The population of interest included adults potentially eligible to receive an ICD for primary prevention of SCD (i.e., adults with no known history of SCD or ventricular tachyarrhythmia). If the study included patients receiving ICDs for secondary prevention, the articles had to provide results by subgroups or specify that the proportion of secondary prevention was less than 20 percent. Participants had to be followed from the time of ICD implantation, not only from some arbitrary time after ICD implantation. There was no minimum followup duration.

For Key Question 1a, comparisons of interest were ICD versus no ICD (i.e., medical management with a designated comparator drug or with concomitant medical therapy). For this review, we included studies comparing CRT-D versus CRT alone as a comparison of ICD versus no ICD. For Key Question 1b, comparisons of interest were ICD with ATP versus ICD alone, or ICD with CRT CRT versus ICD versus ICD alone. We did not review comparisons of different pacing or shock algorithms.

For Key Question 1c, we examined effect modification in subgroups. In studies eligible for Key Questions 1a and 1b, we examined the results across subgroups for different patient characteristics such as varying demographic features (age, sex, race, and ethnicity), major comorbidities, different risk factors for SCD, or different indications for ICD implantation (including LVEF ≥30 versus < 30 percent, duration of QRS interval, NYHA heart failure classification, and type of underlying heart disease [e.g., ischemic vs. nonischemic cardiomyopathy]); time from MI; different numbers of leads; different characteristics of clinicians implanting ICDs—that is, different levels of training and experience; and different characteristics of facilities where ICDs are implanted, such as patient volume and presence or absence of a training program. We planned to evaluate subgroups that were of particular interest to CMS upon setting up the ICD registry: patients with LVEF of 31 to 35 percent, patients with nonischemic cardiomyopathy of less than 9 months' duration, and patients with NYHA class IV heart failure who may benefit from an ICD with CRT. Studies had to report how a difference in the factor affected outcomes of interest (e.g., death rates in subgroups based on age ranges), not the groups' baseline characteristics on the basis of the outcome (e.g., mean ages at ICD implantation among patients who survived or died). We examined whether estimates differed statistically significantly across subgroups.

For all of Key Question 1, outcomes of interest were clinical outcomes including death from SCD, all-cause mortality, sustained ventricular tachyarrhythmia, quality of life (QoL), and other patient-reported outcomes. We excluded heart failure outcomes as well as composite outcomes of death and heart failure. For QoL and other patient-reported outcomes, we gave priority to measurements made with standardized and validated instruments.

### Key Question 2

For rates of adverse events, we included longitudinal studies of any design with at least 500 participants. This criterion was set because the rate of adverse events is low and because we were able to use a registry for in-hospital adverse events. Participants had to be followed from the time of ICD implantation, not only from some arbitrary time after ICD implantation. There was no minimum followup duration. For comparison of rates of different ICD devices we reviewed comparative studies with at least 10 patients per arm that were included in Key Question 1b.

The population of interest was adults who received an ICD for primary prevention alone, preferentially, or for either primary or secondary prevention, if not separately reported. A mix of primary and secondary prevention was permitted because we determined that there is little reason to expect adverse events to differ between primary prevention and secondary prevention populations and that the addition of patients with ICDs for secondary prevention would allow for better estimates of adverse event rates. However, studies specifying ICD implantation only for secondary prevention were excluded. We also excluded studies published prior to 2002, because we aimed to focus on harms associated with current devices and implantation methods.

Interventions of interest were the same as those for Key Question 1: single-chamber, dual-chamber, or biventricular ICDs with or without ATP or CRT. The outcomes of interest for adverse events are listed below, divided into those that occur early after ICD implantation (including events that occur during the hospital stay for implantation or up to 30 days postimplantation) and those occurring later:

- Early (during hospitalization for ICD implantation)
  ○ Any adverse event
  ○ Any adverse event or death
  ○ Any serious adverse event
  ○ Atrioventricular fistula
  ○ Cardiac arrest
  ○ Cardiac perforation
  ○ Cardiac valve injury
  ○ Cerebrovascular accident/Stroke
  ○ Conduction block
  ○ Coronary venous dissection
  ○ Drug reaction
  ○ Hematoma
  ○ Hemothorax
  ○ Infection related to device
  ○ Lead dislodgement
  ○ Myocardial infarction
  ○ Pericardial tamponade
  ○ Peripheral embolism
  ○ Peripheral nerve injury
  ○ Phlebitis - deep
  ○ Phlebitis - superficial
  ○ Pneumothorax
  ○ Transient ischemic attack
- Late (after hospitalization for implantation)
  ○ Device malfunction
  ○ Device or lead revision
  ○ Lead dislodgement
  ○ Lead fracture or malfunction
  ○ Infection related to device
  ○ Thrombosis
- Inappropriate shocks

For adverse events occurring early after the implantation procedure (during hospitalization), we reviewed and reconciled reports from the NCDR ICD database. This registry was started after the 2005 Medicare coverage decision and provides standardized, comprehensive data on over 90 percent of ICD implantations in the United States with active and passive ascertainment for adverse events during the hospitalization for the implantation.79 We included all pertinent reports from the registry even though there was overlap in participants across publications.

For adverse events occurring after hospitalization, we included cohort studies with ICD groups, including ICD arms from RCTs. Since the adverse events of interest are unique to the ICD or the implantation procedure, we did not extract data on control arms without ICDs. For information on how adverse events differ across ICD types, we tabulated the adverse events reported in eligible comparative studies from Key Question 2.

We further searched for any information on effect modifiers that might increase or decrease the risk of adverse events. Subgroups or factors of interest were different patient characteristics (age, sex, race, diabetes, end-stage renal disease), different ICD characteristics (including ATP or CRT features and number of leads), different characteristics of clinicians implanting the ICDs (different levels of training and experience), and different characteristics of facilities where ICDs are implanted. For subgroups, we again included only data reported on the basis of the factor, not on the basis of the outcome, and examined whether estimates differed statistically significantly across subgroups.

### Key Question 3

For Key Question 3a, related to the eligibility criteria and prior evaluation of participants, we reviewed the studies used to address Key Question 1 and tabulated the descriptive information about how patients were evaluated prior to enrollment and randomization. For Key Question 3b, we evaluated the studies reviewed for Key Question 1 and captured the number of total shocks and ATP pacing events as an indicator of the underlying severity of disease (i.e., the likelihood of SCD) in patients analyzed in studies to assess treatment heterogeneity across studies. Note that the number of inappropriate shocks, a measure of harm, is covered in Key Question 2.

## Article Screening and Data Extraction

We screened titles and abstracts using Abstrackr (http://sunfire34.eecs.tufts.edu).80 Seven researchers double-screened the abstracts after iterative training of all reviewers on several batches of abstracts. Discordant decisions and queries were resolved at group meetings. Full-text articles were retrieved for all potentially relevant abstracts. Studies excluded during full-text screening and the reasons for exclusion are given in Appendix B.

Each study was extracted by one experienced methodologist. The extraction for results and quality were reviewed and confirmed by at least one other methodologist. Data extraction was done using the Systematic Review Data Repository (SRDR) database (www.srdr.ahrq.gov).81 The form was customized to capture all relevant elements for the key question and included elements for population characteristics, sample size, study design, descriptions of the ICD and comparison interventions, outcomes, subgroup factors, and relevant results analyses. We also extracted data on items of particular relevance to Key Question 3, such as eligibility criteria and how patients were evaluated.

For data from survival curves, we extracted both the reported hazard ratio (HR), preferentially the adjusted HR rather than the unadjusted HR, and any reported counts data. We did not digitize figures to estimate counts or percentages of outcomes. We used the maximum duration of the survival curve as the duration of followup for each relevant outcome, unless the article explicitly expressed the HR as applying to a different timepoint. For outcomes with data reported at multiple timepoints, our a priori timepoints of interest for clinical outcomes were 1, 2, and 4 years of followup. In our meta-analyses (described below), we also analyzed data from all years of followup with data.

## Risk of Bias and Quality of Reporting Assessment

For Key Question 1, we assessed methodological quality of RCTs using eight items derived from the Cochrane risk of bias tool82 and one additional item created to address participant crossovers during the study period (Table 1). Reviewing across all eight risk of bias items, we assigned an overall quality grade of good, fair, or poor to each RCT. We assigned particular weight to risk of bias concerns related to differential attrition or crossover between arms and to differences other than ICD assignment between the two arms. We downgraded for risk of bias related to outcome assessor blinding only for clinical outcomes other than all-cause mortality. We did not grade nonrandomized comparative studies (nRCS).

Table 1 Risk of bias items assessed for randomized controlled trials (Key Question 1)

1. What is the risk of selection bias (biased allocation to interventions) due to inadequate generation of a randomized sequence?; 2. What is the risk of selection bias (biased allocation of interventions) due to inadequate concealment of allocations before assignment?; 3. For each main outcome or class of outcomes, what was the risk of detection bias due to knowledge of the allocated interventions by outcome assessment (lack of outcome assessor blinding)?; 4. For each main outcome or class of outcomes, what is the risk of attrition bias due to amount, nature, or handling of incomplete outcome data?; 5. Were all randomized participants analyzed in the group to which they were allocated?; 6. Were the groups similar at baseline regarding the most important prognostic indicators?; 7. Were co-interventions avoided or similar?; 8. Are there other risks of bias? If yes, describe them in Notes.; 9. Number of crossovers?

For Key Question 2, we assessed the quality of reporting of harms using items adapted from the McMaster Quality Assessment Scale of Harms (McHarm) Tool (Table 2).83,84

Table 2 Quality of reporting items assessed for adverse event studies (Key Question 2)

1. Were any harms pre-specified (a priori) in methods section?; 1a If yes, were any of them pre-specified with a priori standardized or precise definitions?; 2. Were all pre-specified harms reported?; 3. Was the mode of harms collection active (sought to collect information on adverse events)?; 4. Was the mode of harms collection passive? (Participants are not specifically asked about or tested for the occurrence of adverse events. Rather, adverse events are identified based on patient reports made on their own initiative.); 5. Did the study specify the timing and/or frequency of collection of harms?; 6. Is the number of participants who experience harms provided for each arm?; 7. Is the number at risk for harms (denominator) provided for each arm?; 8. For comparative studies (those also addressing Key Question 1): Is there statistical analysis of relative harms between groups?

## Data Synthesis

We summarized all included studies in narrative form as well as in evidence tables that summarize the important features of the study design, population characteristics, results, study quality, and inclusion criteria. Tables in Appendix C provide detailed baseline characteristics of the included patients and cointerventions given at baseline, the qualitative results summary, the quality of each study, and the results for Key Question 3 (See Table of Contents for Appendix C).

For outcomes with at least three RCTs with sufficiently similar comparisons of interventions and comparators (relevant to Key Question 1), we performed DerSimonian & Laird random effects model meta-analyses.85 We meta-analyzed adjusted HRs, unadjusted HRs (if no adjusted HR was reported), and estimated HRs (if no HR was reported). To estimate the HR, we used the various methods described by Tierney et al. to estimate HR given different types of reported data.86 For these calculations, only reported counts (events) were used; we did not use digitized data from figures. For each meta-analysis the statistical heterogeneity was assessed with the I^2^ statistic, which describes the percentage of variation across studies that is due to heterogeneity rather than chance.87,88

For our primary meta-analyses, we included only studies that included only patients who meet current practice for ICD use for primary prevention, thus excluding studies of patients undergoing ICD implantation immediately after coronary revascularization or early after recent myocardial infarction. We conducted sensitivity analyses in which we added back in the RCTs of these “atypical” patients.

To assess how the effect of ICD versus no ICD changes over time since randomization we drew plots of the difference in cumulative mortality between ICD and no ICD based on the reported Kaplan Meier plots for each trial. At each year timepoint we estimated the cumulative death proportion by digitizing the figure for both ICD and no ICD and subtracted the no ICD cumulative death proportion from the ICD proportion. This calculation measures the vertical distance between the two curves in the Kaplan Meier plots. To roughly estimate the average difference in cumulative death across studies we calculated a weighted mean of the differences at each annual time point based on the numbers of people remaining at risk within each study at each timepoint.

For each RCT of ICD versus no ICD, we calculated the numbers-needed-to-treat (NNT) to prevent one death (all-cause) and to prevent one tacchyarrhythmia death. Since most RCTs reported HRs for death, we estimated the NNT for each trial to prevent one death at each year from reported or estimated HRs. To estimate NNT from HR, we used the method described by Altman et al, which estimates the control and treatment rates from the HR, the survival rate at each year, and the number at risk at each year.89 Since the control rates across studies varied widely, we did not meta-analyze NNT as the summary NNT value would be uninterpretable without a single value for the control rate as a referent.

In regards to subgroup analyses, for each study that reported odds ratios (or relative risks or hazard ratios) for the same or similar pairs of subgroups (e.g., women vs. men, age ≤60 or 65 years vs. >60 or 65 years), we calculated a “relative odds ratio” as the ratio of the odds ratio (or similar metric) of one subgroup to the other subgroup, and its 95 percent confidence interval. When at least three studies reported sufficient data for pairs of similar subgroups, we meta-analyzed these using a random effects model.

## Strength of Evidence Grading

We followed the Methods Guide to evaluate the strength of the body of evidence for Key Questions 1 and 2 with respect to four domains: risk of bias, consistency, directness, and precision.78,90 Briefly, we defined the risk of bias (low, medium, or high) on the basis of the study design and the methodological quality of the studies. Where there was sufficient evidence from RCTs, we determined strength of evidence from these alone, without considering the nRCSs.

For consistency we did not use rigid counts of studies as standards of evaluation (e.g., four of five studies agree, therefore the data are consistent); instead, we assessed the direction, magnitude, and statistical significance of all studies for each specific topic and made a qualitative determination.

Since we examined clinical and patient-reported outcomes (and clinically important adverse events), we expected all analyzed evidence to be “direct.” Where applicable, we considered the degree to which conclusions are based on direct comparisons (within studies) or indirect comparisons across studies).

We assessed the precision of the evidence as precise or imprecise on the basis of the degree of certainty surrounding each effect estimate. A precise estimate is one that allows for a clinically useful conclusion. An imprecise estimate is one for which the confidence interval is wide enough to include clinically distinct conclusions (e.g., both clinically important superiority and inferiority—a situation in which the direction of effect is unknown) and that therefore precludes a conclusion.

We rated the body of evidence on the basis of four strength-of-evidence levels (high, moderate, low, and insufficient90) to indicate our level of confidence that the evidence reflects the true effect for the major comparisons of interest.

A high strength of evidence suggests that we are very confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies. We believe that the findings are stable.

A moderate strength of evidence suggests that we are moderately confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies. We believe that the findings are likely to be stable, but some doubt remains.

A low strength of evidence suggests that we have limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both). We believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.

A ranking of insufficient evidence suggests that we have no evidence, we are unable to estimate an effect, or we have no confidence in the estimate of effect for this outcome. No evidence is available or the body of evidence has unacceptable deficiencies, precluding judgment. We graded the body of evidence to be insufficient to assess a strength of evidence if evidence was either unavailable or did not permit estimation of an effect because of lacking or sparse data or if the data were too inconsistent or inconclusive to determine whether there was evidence of a benefit, a harm, or no difference between intervention and comparator. In general, when only one study had been published, the evidence was considered insufficient, unless the study was particularly large, robust, and of good quality.

We reviewed subgroups results for Key Question 1 and 2 for statistically significant differences. Subgroup analyses are by their nature exploratory. Thus we did not grade strength of evidence of the subgroup results.

## Applicability

We followed the Methods Guide to evaluate the applicability of included studies to patient populations of interest.78,90 We highlighted limitations to applicability when comparing the populations in the included studies with the core Medicare population.

## Peer Review

The draft report was prereviewed by the AHRQ TOO. Following revisions, the draft report was sent to invited peer reviewers and simultaneously uploaded to the AHRQ Web site where it was available for public comment for 2 weeks. All reviewer comments (both invited and from the public) were collated and individually addressed. The revised report and the EPC's responses to invited and public reviewers' comments were again reviewed by the TOO prior to completion of the report. The authors of the report had final discretion as to how the report was revised on the basis of the reviewer comments, with oversight by the TOO.