# Introduction

## Background

Sudden cardiac death (SCD) is the most common cause of cardiovascular death worldwide, accounting for approximately 300,000 deaths in the United States annually, although estimates have ranged from 200,000 to 450,000 deaths.1-10 The estimate of prevalence depends on the definition and inclusion criteria used in studies.6 Operationally, SCD is most frequently defined as a cardiac death that occurred within 1 hour of cardiac symptom onset and without another probable cause of death. Studies from epidemiological cohorts from the 1970s through the 1990s suggest that 88 to 91 percent of deaths that occur within 1 hour of symptom onset are arrhythmic in nature.11 The temporal definition of SCD strongly influences epidemiological data.6,12 Increasing the time window to 24 hour since symptom onset to define SCD increases the sensitivity but reduces specificity by reducing the proportion of all sudden natural deaths that are due to cardiac causes.

Approximately three-quarters of cases of SCD are caused by ventricular tachyarrhythmias such as ventricular tachycardia (VT) and ventricular fibrillation (VF).2,13,14 Sustained ventricular arrhythmias may lead to hemodynamic instability and abrupt loss of consciousness without spontaneous recovery, requiring cardiac resuscitation (i.e., cardiac arrest). With advancements in cardiopulmonary resuscitation and greater availability of automatic external defibrillators, it is possible to “abort” SCD. Nonetheless, only 3 to 10 percent of patients who have an out-of-hospital cardiac arrest are successfully resuscitated.15 Timely administration of therapy is essential, as the rate of survival for people with VF declines by approximately 10 percent per minute.5,16 Even for those out-of-hospital arrests who survive to hospitalization, survival to hospital discharge is less than 8 percent.5,17,18

Prevention is the primary strategy to lower death from SCD. However, SCD is a particular management challenge because the majority of cases occur in individuals without a prior diagnosis of cardiac disease or other clear risk factors for SCD. The most common underlying cardiovascular diagnosis among people with SCD is coronary artery disease (CAD). Yet, in about half of the cases of SCD, SCD itself is the initial manifestation of CAD.1,4-6 The clinical strategy to prevent death from SCD involves identification of risk factors for ventricular tachyarrhythmias and SCD, to target individuals for medical and interventional treatments.

### Outcomes Adjudication

There is the potential to misclassify SCD; thus, to interpret trial results, it is important that studies clearly define their primary and secondary outcomes and follow rigorous methods of adjudication. The most unambiguous outcome with regard to classification is death from any cause or total mortality; this is therefore a common outcome. Arguably, all-cause death is the principal outcome of interest to patients and their families, even though the goal of ICD implantation is to prevent specifically SCD or death from arrhythmia. SCD is a common secondary outcome in ICD trials. However, determination of cause-specific mortality may be fraught with errors. From the Framingham Heart Study, it is suggested that SCD rates derived from death certificates alone should be interpreted with caution.19 In clinical trials, adjudication of arrhythmia or SCD can be very involved requiring validation by blinded committees which independently adjudicate all deaths according to algorithms and consensus

Criteria for adjudication of SCD were originally developed by Hinkle and Thaler20 and previously validated in the Canadian Implantable Defibrillator Study21 and the Canadian Amiodarone Myocardial Infarction Arrhythmia Trial.22 These criteria are based on the clinical circumstances of death and do not rely on ICD information. Documentation of the cause of death may further incorporate information obtained from witnesses, relatives and family members, death certificates, hospital records, and autopsy reports where available.

### Risk Factors for SCD

Risk factors for SCD are multifactorial, dynamic, and associated with a continuous risk function.23 Some risk factors are nonmodifiable, such as sex and family history of CAD.24 The incidence of SCD increases as a function of advancing age. The incidence is 100-fold less in young adults less than 30 years of age as compared with older adults.6,25-28 In regard to the development of disease processes, the Framingham Heart Study revealed that CAD is associated with a 2.8- to 5.3-fold increase in risk of SCD. Following myocardial infarction, there is a 4-fold higher risk of SCD for women and a 10-fold higher risk of SCD for men.11 Mortality following ST-segment elevation myocardial infarction (MI), in particular, is high with an especially high risk of SCD in those patients with left ventricle dysfunction in the first 30 days.29 Modifiable CAD risk factors that have been demonstrated to predict SCD include hypertension, hypercholesterolemia, and diabetes.11 In regard to hypertension which is both an established risk factor for CAD and SCD, both the electrocardiogram pattern of left ventricular hypertrophy and echocardiographic evidence of left ventricular hypertrophy are associated with a higher proportion of sudden and unexpected cardiac death.6 There are also meaningful associations between cigarette smoking, obesity, lifestyle and SCD. For instance, in a study of 310 survivors of out-of-hospital cardiac arrest, the recurrent cardiac arrest rate was 27 percent at 3 years of follow-up among those who continued to smoke as compared with 19 percent in those who stopped.30

The Framingham Heart Study also showed that congestive heart failure is associated with a 2.6- to 6.2-fold increased risk of SCD.11,31 Other disease processes that impart a variable risk of SCD are cardiomyopathies such as dilated, hypertrophic, and arrhythmogenic right ventricular cardiomyopathy as well as primary electrical disorders such as long QT syndrome and Brugada syndrome. Population-based studies have demonstrated that electrocardiography criteria such as an elevated resting heart rate,32 prolonged QRS duration,33,34 and prolonged QT interval increase SCD risk in the general population.11,35,36

Currently, the single most widely used risk stratification criterion, based on multiple randomized controlled trials, is a reduced left ventricular ejection fraction (LVEF), typically a value of ≤30 or ≤35 percent.23 From a pathophysiologic standpoint, the presence of scar tissue is known to be a substrate for ventricular tachyarrhythmias. Molecular, cellular and interstitial changes play a role in myocardial remodeling. One of the challenges of better risk stratification is the fact that different pathophysiological processes may lead to ventricular tachyarrhythmias and subsequently SCD. Thus, the predilection toward a ventricular arrhythmia is complex and cannot be entirely defined by a single dichotomous variable such as LVEF. Further, the greatest absolute number of SCD events will occur in people without known risk factors or with SCD as the first manifestation of cardiac disease.14,37 In one study which examined patients who had a cardiac arrest, approximately 65 percent would not have qualified for a primary prevention ICD prior to the event.38 Thus, there is a great need for improved risk stratification tools. Attempts have been made to calculate SCD risk score models such as one derived from Multicenter Automatic Defibrillator Implantation Trial (MADIT)II as well as the Duke risk score in patients with coronary artery disease. The risk scores may be helpful in guiding therapy for a physician but they have not been applied in a prospective manner in clinical trials.39,40

An example of an invasive risk stratification tool which has been studied prospectively in Multicenter Unsustained Tachycardia Trial (MUSTT)41 and MADIT42 is the electrophysiology study. MUSTT provided evidence that electrophysiologically guided antiarrhythmic therapy with ICDs reduces the risk of SCD in high-risk patients with CAD, LVEF ≤40 percent, spontaneous and unsustained VT, or sustained tachyarrhythmia induced by programmed stimulation. MADIT42 included patients with CAD and a prior MI, LVEF ≤35 percent, and inducible, sustained VT or VF at electrophysiologic study.42 Thus, the electrophysiology study has a tailored role in risk prediction.

### Medical and Interventional Treatment for Prevention of SCD

Prevention strategies include risk factor modification and treatment of the underlying disease processes of CAD, congestive heart failure, and cardiomyopathy with medical therapy. Medical therapy includes the use of aspirin, beta blockers, angiotensin converting enzyme inhibitors, angiotensin receptor blockers, aldosterone blockers, and statins. In addition, reperfusion therapies for MI such as tissue plasminogen activators and percutaneous coronary intervention for CAD have resulted in a significant decline in SCD over the past 30 years.43

Antiarrhythmic drugs have also been used in an attempt to lower the risk of SCD. These medications can effectively suppress abnormal rhythms; however, suppression of arrhythmias with these drugs has not been found to translate into improved survival. In fact these medications have no effect or can increase the risk of SCD. The Cardiac Arrhythmia Suppression Trial (CAST) showed that suppression of spontaneous ventricular arrhythmias with antiarrhythmic agents in high-risk patients after MI resulted in an excess mortality.44,45 Studies of other antiarrhythmic drugs such as D-sotalol46 and dronedarone47 have also resulted in mortality concerns. Amiodarone has not been associated with improved survival in high-risk patients after MI (in two trials, European Myocardial Infarction Amiodarone Trial [EMIAT]48 and Canadian Amiodarone Myocardial Infarction Arrhythmia Trial [CAMIAT],22 nor has it resulted in improved survival when compared to an implantable cardioverter–defibrillator (ICD) in patients who had a prior cardiac arrest (in the Cardiac Arrest Study Hamburg [CASH],49 Canadian Implantable Defibrillator Study [CIDS],21 and Antiarrhythmics versus Implantable Defibrillators [AVID]50 trials). The Sudden Cardiac Death in Heart Failure Trial (SCD-HeFT) showed no survival benefit from amiodarone for primary prevention of SCD when compared with placebo.51 Furthermore, the use of amiodarone can cause long-term harms involving lung, liver, thyroid, and skin. Given the excess adverse events from antiarrhythmic therapy, antiarrhythmic drugs currently are only selectively administered in some patients to reduce symptoms from recurrent ventricular arrhythmias, without the intention to improve mortality.

In this setting of inadequate medical treatment of ventricular tachyarrhythmias, another treatment option is device therapy. In 1980, Mirowski et al. developed a paradigm of interventional treatment with the development of the ICD,52 a medical device designed to prevent SCD by terminating ventricular tachyarrhythmias and subsequently aborting cardiovascular collapse and death.

### ICD Technology

The ICD is a battery-powered implantable device that consists of a generator and one or more leads capable of sensing a ventricular arrhythmia and delivering therapy in the form of an electric shock. This electric shock causes defibrillation when a potentially life-threatening arrhythmia is detected, to terminate the arrhythmia and prevent SCD. Over the years, ICD technology has evolved in several ways. Over time, the size of the device, or footprint, has become significantly smaller. With improved technology, large abdominal generators have been replaced by smaller pectoral generators. Furthermore, the ICD lead was initially designed as an epicardial patch, which required opening the chest for surgical implantation. At present, right atrial, right ventricular, and left ventricular leads may all be placed endocardially via a transvenous approach, obviating the need for thoracotomy or sternotomy in most cases.

Over the past decade, there has also been an evolution in ICD technology. ICDs were initially designed as single chamber devices with the sole purpose of providing an electric shock to terminate a lethal ventricular rhythm. These devices can now incorporate pacing capabilities to provide backup ventricular pacing. A dual chamber device (with a lead in the right atrium and a lead in the right ventricle) may be implanted to impart atrial and ventricular synchrony in patients who meet indications for a dual chamber pacemaker (i.e., those with certain types of bradycardia) as well as defibrillator therapy.

Currently, device-based therapy also includes the ability to deliver cardiac resynchronization therapy (CRT) via the addition of a left ventricular lead. CRT may be delivered in the form of a standalone biventricular pacemaker (CRT-P) or in addition to an implantable cardioverter defibrillator (CRT-D). CRT implantation involves the placement of right atrial, right ventricular, and left ventricular leads. The difference between CRT-P and CRT-D relates to the type of right ventricular lead (with or without coils) and the type of generator. The goal of CRT is to improve cardiac output in patients who manifest electrical dyssynchrony and cardiac dysfunction via atrial-synchronized biventricular pacing towards improving congestive heart failure and related symptoms as well as prolonging survival. While patients at increased risk for SCD and those who have dyssynchrony share some characteristics, they are not exactly the same clinical populations. The goals of ICD and CRT therapy overlap in their overall goal to improve meaningful survival, but they are distinct in that the intention of ICD therapy is restoration of normal sinus rhythm in the setting of life-threatening arrhythmias, and the intention of CRT is improvement of functional status and symptoms of heart failure.

Technological advances have taken place not only in the design of the generator and the leads but also in software algorithms. One of the goals of these algorithms is to avoid “inappropriate” shocks, shocks that are delivered when ventricular tachyarrhythmias are not occurring. This can occur when there is a fast rhythm that is actually supraventricular (atrial) in origin rather than ventricular. To prevent these inappropriate shocks, ICD programming has been developed to discriminate among types of tachyarrhythmias and to differentiate atrial from ventricular arrhythmias. An inappropriate shock may also be delivered as a result of electromagnetic interference or a lead or device malfunction.

Further developments that combine pacing capabilities with sophisticated programming algorithms include the ability to treat ventricular tachycardias via antitachycardia pacing (ATP). ATP is achieved by pacing the ventricle at a cycle length faster than the ventricular tachyarrhythmia in an attempt to abort the rhythm. Because ICD shocks are painful and are associated with patient morbidity,53-55 ATP offers the potential to terminate the abnormal rhythm in a painless manner without the need for an electrical shock. On the other hand, ATP may accelerate a VT resulting in the degeneration of the rhythm into VF. The safety and efficacy of ATP has been evaluated in multiple studies.56-59 Most recently, MADIT-RIT (Multicenter Automatic Defibrillator Implantation Trial: Reduce Inappropriate Therapy) examined effect of ICD programming on inappropriate therapy and mortality.60

### ICD Complications

Any potential benefits have to be balanced against potential harms. Implantating a cardiac electronic device is an invasive procedure with inherent risks. There is the potential for intraoperative or immediate postoperative complications, including but not limited to bleeding, infection, pneumothorax, cardiac tamponade, or lead dislodgement.61-65 Long-term complications include lead or generator malfunction, thrombosis of the access site, infection, and inappropriate ICD shocks that may have emotional and psychological repercussions. In addition to patient characteristics, physician characteristics such as training and volume may play a role in complications rates.66,67

### ICD Use for Secondary Prevention of SCD

Persons with sustained VT and survivors of out-of-hospital cardiac arrest have an actuarial incidence of SCD at 2 years of 15 to 30 percent.11,68 Initial use and testing of ICDs was performed in this group of patients who had already experienced a sustained ventricular tachyarrhythmia or SCD and were at high risk of recurrence. This scenario of preventing SCD recurrence is called secondary prevention of SCD. A meta-analysis of three randomized controlled trials (CASH,49 CIDS,21 and AVID50) of antiarrhythmic therapy versus ICD in this population revealed a 28 percent reduction in the relative risk of death with the ICD.

The current 2008 joint American College of Cardiology Foundation/American Heart Association guidelines for device-based therapy state that ICD therapy is indicated in patients who are survivors of cardiac arrest due to VF or hemodynamically unstable sustained ventricular tachyarrhythmia following exclusion of completely reversible causes.69

### ICD Use for Primary Prevention of SCD

ICDs have begun to be used in patients with no prior episode of sustained ventricular tachyarrhythmia or SCD but who are considered to be at high risk for SCD. As noted above, the majority of cases of SCD occur in people with no known history of VT or VF. Thus, primary prevention (i.e., preventing a first occurrence) of SCD is of paramount importance.

### Current Guidelines

In 2008, a joint task force of the American College of Cardiology Foundation (ACCF)/American Heart Association (AHA)/Heart Rhythm Society in collaboration with the American Association for Thoracic Surgery and Society of Thoracic Cardiac Pacemakers and Antiarrhythmia Devices updated the 2002 guidelines for device-based therapy.2,70 According to these clinical guidelines, class I indications for ICD therapy for primary prevention of SCD include 1) Patients with LVEF ≤35 percent due to prior MI who are at least 40 days post-MI and are in NYHA Class II or III; 2) Patients with nonischemic dilated cardiomyopathy who have an LVEF ≤35 and who are in NYHA Class II or III. 3) Patients with LV dysfunction due to prior MI who are at least 40 days post-MI, have an LVEF ≤ 30 percent, and are in NYHA Class I.70 These clinical indications correlate with the coverage criteria set by CMS.

This review is focused on primary prevention of SCD and does not provide a comprehensive assessment of the effectiveness of CRT for management of heart failure or dyssynchrony. However, given overlapping indications for CRT and ICD therapy, it is important to note that in October 2012, a joint ACCF/AHA task force on practice guidelines published a focused update, revising its 2008 guidelines.71 Recommendations specifically for CRT were updated on the basis of multiple heart failure trials in the 2012 Focused Update for Device-Based Therapy of Cardiac Rhythm Abnormalities; ACC/AHA Guidelines for the Management of Patients with Heart Failure; and ICD Indications.72-74 New recommendations and modifications focused on heart failure status, QRS duration, left versus non-left bundle branch block, and underlying rhythm (sinus rhythm vs. atrial fibrillation). In addition, the Appropriate Use Criteria have been published based on a 2013 HRS-ACC-AHA Expert Consensus on ICD Indications Outside of Current Guidelines.75 This document assessed levels of appropriateness for implanting ICDs and CRTs in 369 real-life case scenarios, to provide guidance concerning the decision to implant ICDs and CRT devices in a variety of clinical scenarios where there are gaps in guidelines. The AUC document should be used in conjunction with the ACC/AHA/HRS 2008 Guidelines for Device-Based Therapy of Cardiac Rhythm Abnormalities and the 2012 Focused Update.

### CMS Coverage Decisions for Primary Prevention

CMS issued coverage decisions for ICD implantation for primary prevention which are reviewed here since they have shaped subsequent research and clinical care. In 2003, CMS provided coverage for primary prevention of SCD, primarily on the basis of data from the Multicenter Automatic Defibrillator Implantation Trial (MADIT)42—which included patients with CAD and a prior MI, LVEF ≤35 percent, and inducible, sustained VT or VF at electrophysiologic study—and from MADIT II76—which included patients with prior MI and, LVEF ≤30 percent.

The 2005 CMS national coverage determination broadened the indications for implantation of ICDs for primary prevention of SCD.77 In addition to the above criteria, it added the following indications:

- Documented prior MI and a LVEF ≤30 percent
- Ischemic dilated cardiomyopathy, prior MI, New York Heart Association (NYHA) class II or III heart failure, and LVEF ≤35 percent
- Current CMS coverage requirements for a CRT device, together with ambulatory NYHA class IV heart failure
- Nonischemic dilated cardiomyopathy for >3 months, NYHA class II or III heart failure, and LVEF ≤35 percent.

To be covered, a patient must also be receiving optimal medical therapy and have reasonable expectation of survival with good functional capacity for more than 1 year.

As part of its coverage determination, Medicare instituted a requirement for the CMS to establish an ICD registry to collect data on individuals undergoing ICD implantation to be able to assess outcomes after ICD implantation. Thus, the National Cardiovascular Data Registry (NCDR) ICD registry has been active since 2005.

### Current Uncertainties

The field of ICD implantation for primary prevention of SCD is evolving as clinicians are challenged by decisions about how to direct it to patients who may derive net benefit. A number of recent developments may have impacted the risk benefit ratio. With the 2005 coverage decision, the pool of patients eligible for implantation has expanded. Selection criteria have changed with earlier trials selecting patients based on invasive electrophysiological testing, while more recent studies selected patients solely based on clinical selection criteria. Meanwhile, technology has advanced to newer generations of devices. While the risk of SCD is highest in the first few weeks after MI in patients with left ventricular dysfunction, there has been a decrease in the SCD and mortality after MI as a result of medical and percutaneous coronary interventional advances.29,43 This highlights the need for an updated evaluation of the aggregate data on ICD benefits and harms and how they apply to particular patient subgroups.

## Aim of the Technology Assessment

This Technology Assessment examines the state of evidence related to ICD use for primary prevention of SCD. It examines the effectiveness of treatment with an ICD versus control treatment without an ICD. It also examines the effectiveness of combining an ICD with ATP or with CRT versus an ICD alone.

## Key Questions

This Technology Assessment considers evidence regarding the following three Key Questions, based on those originally drafted by CMS and refined through discussions with the Agency for Healthcare Research and Quality (AHRQ) and CMS:

### Key Question 1

a. In candidates for ICD implantation for primary prevention of SCD, what are the effects of ICD compared with no ICD therapy on clinical outcomes and patient-reported outcomes?
b. In candidates for ICD implantation for primary prevention of SCD, what are the effects of ICD with ATP versus ICD alone, or of ICD with CRT versus ICD alone on clinical outcomes and patient-reported outcomes?
c. How do outcomes vary within the following subgroups?
  i. Different patient characteristics such as varying demographic features, major comorbidities, different risk factors for SCD, or different indications for ICD implantation
  ii. Different ICD characteristics
  iii. Different characteristics of clinicians implanting ICDs—that is, different levels of training and experience
  iv. Different characteristics of facilities where ICDs are implanted

### Key Question 2

a. What are the adverse events related to treatment with an ICD for primary prevention of SCD? Specifically:
  i. Early (during hospitalization for implantation)
  ii. Late
  iii. Inappropriate shocks
b. How do adverse events vary within the following subgroups?
  i. Different patient characteristics such as varying demographic features and major comorbidities
  ii. Different ICD characteristics
  iii. Different characteristics of clinicians implanting ICDs—that is, different levels of training and experience
  iv. Different characteristics of facilities where ICDs are implanted

### Key Question 3

Which patients have been included in comparative studies of ICDs for primary prevention of SCD?

a. What were eligibility criteria for patients in studies included for Key Question 1? How were patients evaluated and what diagnostic tests and algorithms were used to select patients?
b. Among patients in studies included for Key Question 1, what was the likelihood of SCD or ventricular tachyarrhythmia, as measured by total shocks for those with ICDs or episodes of SCD for those without ICDs?