# Peer Reviewers

We wish to acknowledge individuals listed below for their review of this report. This report has been reviewed in draft form by individuals chosen for their expertise and diverse perspectives. The purpose of the review was to provide candid, objective, and critical comments for consideration by the EPC in preparation of the final report. Synthesis of the scientific literature presented here does not necessarily represent the views of individual reviewers.

- Robin Boineau, MD, MA
  Medical Officer
  National Heart, Lung, and Blood Institute
  National Institutes of Health
  Bethesda, Maryland
- Paul Heidenreich, MD, MS
  Professor of Medicine
  Stanford University
  Palo Alto, California
- Rita F. Redberg, MD, MSc
  Professor of Medicine
  UCSF Medical Center
  San Francisco, California
- Lynne Warner Stevenson, MD
  Director Cardiomyopathy/Heart Failure Program
  Professor of Medicine
  Brigham and Women's Hospital
  Harvard Medical School
  Boston, Massachusetts
- Ralph J. Verdino, MD
  Associate Professor of Medicine
  University of Pennsylvania
  Philadelphia, Pennsylvania