# Discussion

## Key Findings and Strength of Evidence

We identified 14 studies comparing ICD versus no ICD, 4 studies comparing CRT-D versus ICD, and 59 studies contributing data on adverse events after ICD implantation. The summary of key findings and strength of evidence is shown in Table 20. This table is an amalgamation of Tables 3, 7, and 10, plus outcomes with insufficient evidence.

Table 20 Summary of findings

Outcome | Study Design: No. Studies (N) | Findings | Strength of Evidence
All-cause mortality | ICD vs. no ICD RCT: 10 (8,606) nRCS: 4 (5,949) | - ICD use as primary prevention for patients who meet the current practice criteria (no recent MI, no concurrent coronary revascularization) reduces the risk of all-cause mortality over the course of 3 to 7 years after implantation: HR = 0.69 (95% CI 0.60, 0.79). The benefit of ICD appears fairly stable over time. Across trials, the range of NNT to prevent one death was 6.2 to 22 at 3 to 7 years, with wide 95% CIs.; - There is indirect evidence across studies that patients with recent MIs (<30-40 days), on average, do not benefit from ICD, in contrast with patients with more distant MIs.; - Within-study subgroup analyses fail to support whether the value of ICD placement differs in other subgroups of patients, including by sex or age, or based on different characteristics of facilities where ICDs are implanted. | High
All-cause mortality | CRT-D vs. ICD RCT: 4 (3,743) | - The 2 larger trials found either no difference (HR = 1.00) or a significant benefit with CRT-D (HR = 0.75)No differences in effect were found between patients with ischemic or nonischemic heart disease or with NYHA Class II or III cardiomyopathy; - There was no evidence regarding the comparison of CRT-D and ICD in subgroups of patients or based on different characteristics of facilities where ICDs are implanted. | Insufficient
Sudden cardiac death | ICD vs. no ICD RCT: 7 (4,093)nRCS: 2 (1,115) | - ICD use as primary prevention for patients who meet the current practice criteria (no recent MI, no concurrent coronary revascularization) reduces the risk of SCD over the course of 2 to 6 years after implantation: HR = 0.37 (95% CI 0.26, 0.52). There is insufficient evidence to evaluate the course of the effect over time. Across trials, the range of NNT to prevent one SCD was approximately 2.0 to 11.; - Within-study subgroup analyses fail to support whether the value of ICD placement differs in subgroups of patients or based on different characteristics of facilities where ICDs are implanted. | High
Sustained ventricular tachyarrhythmia | 0 | - There is no evidence | Insufficient
Quality of life | ICD vs. no ICD RCT: 3 (1,825) | - The evidence failed to show a consistent effect of ICD placement on quality of life.; - There is no evidence regarding subgroups. | Low
Early AEs (In-hospital) | RCT: 3 (3,867) Observational: 11 (356,515^†^) [overlapping cohorts] | - During hospitalization, 2.8–3.6% of patients have any adverse event. Serious adverse events occurred in 1.2–1.35% after ICD placement.; - The most common specific adverse events were lead dislodgement (0.7–1.2%) and hematoma (0.8–1.1%). Other in-hospital adverse events occurred in ≤0.5% of patients receiving ICDs; - Based on within-study subgroups analyses, there may be higher rates of adverse events among patients receiving dual-chamber ICDs, CRT-D, among older patients, women, and those with ESRD. Physicians and hospitals with lower volume of implantation and operators other than electrophysiologists may have more adverse events. | High
Late AEs (Out of hospital) | RCT: 3 (2,149) Observational: 28 reports of 22 independent cohorts (99,725^‡^) | - Device-related adverse events occurred in <0.1–6.4% of ICD patients during 2–49 month followup.; - Other relatively common adverse events included lead malfunction (<0.1–3.9% during 1.5–40 month followup), infection (0.2–3.7% for 1.5–49 month followup), and thrombosis (0.2–2.9% for 1.5–49 month followup).; - Based on within-study subgroup analyses, there may be more lead-related adverse events in women. There was no apparent difference in adverse events between CRT-D and ICD or between dual and single chamber ICDs. | Low
Inappropriate shock | RCT: 1 (249) Observational: 21 reports of 17 independent cohorts (212,063^§^) | - Inappropriate shock occurred in 3–21% of patients during 1–5 year followup.; - Based on within-study subgroup analyses, there may be more inappropriate shocks among younger patients. There were mixed data on the difference in inappropriate shocks between dual and single chamber ICDs. Limited data show no apparent difference in inappropriate shocks between CRT-D and ICD, or between dual and single chamber ICDs. | Moderate

AE = adverse event, CI = confidence interval, CMS = Centers for Medicare and Medicaid Services, CRT-D = cardiac resynchronization therapy-defibrillator, ESRD = end stage renal disease, HR = hazard ration, ICD = implantable cardioverter–defibrillator, MI = myocardial infarction, No. =number, nRCS = nonrandomized comparative study, NYHA = New York Heart Association, RCT = randomized, controlled trial, SCD = sudden cardiac death.

† Largest independent N

‡ Largest independent N. Two large cohorts: N=38,992 (PMID 21795298), N=15,387 (PMID 19925609).

§ Largest independent N. One large cohort N=185,778 (PMID 21098452)

Overall, there is a high strength of evidence, with the RCTs and nRCSs showing a consistent and precise benefit of all-cause mortality reduction in selected patients undergoing ICD implantation for primary prevention of SCD compared to those being treated without ICD. The patients who benefit have a combination of reduced LVEF, nonischemic cardiomyopathy and heart failure or a combination of reduced LVED, ischemic cardiomyopathy and at least 30 to 40 days after a MI or 3 months after revascularization. Meta-analysis of seven RCTs yielded a HR of 0.69 (95% CI 0.60, 0.79) for death. Followup ranged from 3 to 7 years. The reported Kaplan Meier curves generally found that the reduction in all-cause mortality with ICD was fairly stable over time. Across RCTs, the NNT to prevent one death at ranged from 6.2 (95% CI 4.0, 18) to 22 (95% CI 2.3, infinite) at the longest durations of followup (3 to 7 years). Three studies of patients who were not in the selected populations because their ICDs were implanted immediately after MI (IRIS102 and DINAMIT98) or were undergoing CABG (CABG-Patch163) did not show a benefit with respect to all-cause mortality. Regarding the outcome SCD, meta-analysis of five studies (again excluding IRIS and DINAMIT) showed benefit from ICD use for reducing SCD (HR 0.37; 95% CI 0.26, 0.52) over the course of 2 to 6 years after implantation. Across RCTs, the NNT to prevent one arrhythmic death ranged from about 2 to 3 (approximate 95% CI 1.3, 16) to 11 (95% CI 1.3, infinite). The evidence suggests that the effect of ICD versus no ICD on SCD over time may increase beyond 2 or 3 years. The finding of a large benefit on SCD, which increased over time, contrasts with a smaller benefit for all-cause mortality, which remained constant over time. This suggests that there are competing risks for mortality in this population limiting the effectiveness of ICDs to reduce death.

Three RCTs of ICD versus no ICD examined QoL with a broad range of QoL measures, but no specific QoL measure was evaluated by more than a single trial. Two of the trials found no difference in QoL with various QoL tools (Health Utility Index 3, Quality of Well-being Schedule, and the State Trait Anxiety Inventory). The third trial found differences favoring no ICD for 2 out of 7 specific components of SF-36 and for perception of health transition. However, this latter trial is of limited applicability to current practice, both because all patients had CABG and because the trial implanted epicardial ICD systems which are much more invasive compared to the transvenous ICDs currently employed. Thus, given the sparseness of data on QoL and the lack of consistency across trials, overall, there is a low strength of evidence low strength of evidence that failed to show a consistent effect of ICD placement on QoL. There is insufficient evidence to evaluate differential effects of ICD on QoL in different populations of patients or based on different characteristics of facilities where ICDs are implanted.

Our analyses failed to show statistically significant differences for all-cause mortality or SCD across subgroups, including by meta-analysis. This contrasts with conclusions by others who proposed differential effects by age and sex. Two prior reviews have proposed no or less benefit from ICDs in women.164,165 One other review concluded that ICDs may be less effective in older adults.172 We believe that these conclusions were based on an over-reliance of within subgroup findings despite nonsignificant interaction tests, study selection (the MUSTT trial included in the review by Ghanbari was unfavorable for women), and lower precision due to women constituting only 23 percent of the study populations.164,166 Our Table 5 and Figures 6 and 7 indicate that the studies consistently found no significant difference in effect between men and women (or other subgroups of patients). However there may be an indication that ICDs are more effective in patients with more distant coronary revascularization compared with recent surgery. Indirect review across studies suggests that patients with recent MIs (within 31 or 40 days) have no reduction in all-cause mortality in contrast with patients with more distant MIs. The evidence fails to support a difference in the benefit of ICD based on time since MI, coronary revascularization, or kidney disease. There is insufficient evidence to evaluate differential effects of ICD on all-cause mortality or SCD in based on different characteristics of clinicians implanting ICDs or facilities where ICDs are implanted. Four RCTs examined the effect of adding CRT to ICD versus ICD alone. Two trials were too small to yield meaningful conclusions regarding death.111,112 MADIT-CRT167 found no difference in all-cause death in patients with ischemic or nonischemic cardiomyopathy. In contrast, RAFT found a significant 25 percent reduction in all-cause death with CRT-D in patients with NYHA Class II or III cardiomyopathy (but no difference in effect between Class II and III).149 Given the inconsistencies between the two studies, there is insufficient evidence regarding how CRT-D and ICD alone compare to prevent all-cause death. Our review examined whether the addition of CRT to ICD impacts mortality. It is important to note that we did not include the review of other outcomes that may be affected by CRT, such as heart failure and related hospitalizations.

We found no study specifically examining the effect of ICD with ATP versus ICD alone for primary prevention. A prior trial compared ICDs with and without ATP for primary or secondary prevention patients and showed benefit for QOL.57 ATP is now a standard software feature available in all modern transvenous ICD systems and can be readily activated by a clinician if deemed appropriate for any given patient. Thus the question of ATP versus no ATP is not as relevant. Instead the more important programming features which have been elucidated by MADIT-RIT are those of rate cut-off and detection delay in addition to the use of ATP.168 MADIT-RIT is discussed in detail below in the section on excluded studies.

We reviewed study eligibility criteria and how the criteria compare to current CMS coverage criteria. Several trials excluded older adults (>70 years to 84 years), whereas two nRCSs included only older adults 65 to 84 years or ≥80 years. All studies used a LVEF criterion but different methods of ascertainment of the EF. IRIS102 included patients with a LVEF <40 percent, but all other studies included only those with LVEF ≤35 percent. The actual mean LVEF at baseline in all studies was below 30 percent. The studies were heterogeneous as to which NYHA Classes (I-IV) were included. The three trials comparing CRT-D versus ICD used QRS interval criteria which varied from ≥130 ms in MADIT-CRT167 ≥120 ms in Diab112 2011 and <120 ms in MENDMI.111 Other approaches to risk stratification for SCD prior to ICD implantation varied across studies. MADIT was the only study that used formal electrophysiological testing.

Although this report's Key Questions did not cover the comparison of the patients in the eligible trials and patients enrolled in the National Cardiovascular Data Registry ICD Registry (NCDR), a recent publication partially does so for patients undergoing primary prevention ICD placement.169 Masoudi et al. provide baseline characteristics data for NCDR, MADIT II, and SCD-HeFT. Although, they did not conduct direct comparisons, notable differences between the trials and NCDR include less frequent NYHA Class III (MADIT II 25% and SCD-HeFT 30%; NCDR 52%), less frequent hypertension (MADIT II 53% and SCD-HeFT 55%; NCDR 75%), less common LBBB (MADIT II 19%; NCDR 29%), and more digoxin use (MADIT II 57% and SCD-HeFT 67%; NCDR 29%). Compared to NCDR, the patients in the trials also had lower mean age (MADIT II 64 years and SCD-HeFT 60 years; NCDR 68 years), lower percentage of women (MADIT II 16% and SCD-HeFT 23%; NCDR 27%), and LVEF (MADIT II 23% and SCD-HeFT 24%; NCDR 25%),.

Six RCTs reported SCD in the control groups that were not assigned to ICD. They found SCD occurring in 4 to 13 percent of patients during 2 to 5 years after randomization. There was no clear trend for increasing rates of SCD with longer followup.

The benefits of ICDs have to be weighed against the risks. A high strength of evidence shows overall early in-hospital adverse event rates ranging from 2.8 to 3.6 percent and serious adverse event rates ranging from 1.2 to 1.35 percent. The most common early adverse events are lead dislodgement (in 0.73 to 1.2% of patients) and hematoma (in 0.84 to 1.1% of patients). Higher rates of in-hospital adverse events have been shown in the following subgroups: patients implanted with dual-chamber ICDs or CRT-Ds (vs. single-chamber ICDs); patients who are older, female, or have ESRD; patients implanted by physicians with a lower implantation volume or by nonelectrophysiologists; and patients implanted at hospitals with a lower implantation volume.

Regarding late (out of hospital) adverse events, there is low strength of evidence that device-related adverse events (with variable definitions) occurred in <0.1 to 6.4 percent of patients for followup durations of 2 to 49 months. Lead-related adverse events occurred in <0.1 to 3.9 percent of patients with followup durations from 1.5 to 40 months, but in 7.0 to 19 percent of patients during longer followup (35 to 96 months). Based on moderate strength evidence, the percentage of patients who experienced at least one inappropriate shock ranged from 3 to 21 percent for followup between 1 and 5 years.

Generally, these risks from ICD identified in this review appear low. However, it is possible there is underreporting for hospital based complications, and a gross underestimation of complications after hospital discharge which are not systematically captured.

## Comparison With Current Knowledge

Our findings for benefit from ICD implantation for primary prevention of SCD are consistent with those in the literature. A prior meta-analysis of the same seven RCTs we combined in our main analysis found a HR of 0.74 (95% CI 0.67, 0.83).170 This estimate differs slightly from our estimate due to selecting different control arms from COMPANION95 and SCD-HeFT.51 Another meta-analysis restricted to five trials in individuals with nonischemic cardiomyopathy found a HR for mortality of 0.69 (95% CI 0.55, 0.87).171

The studies in our review failed to find statistically significant differences in effects across subgroups. Two prior reviews concluded that ICDs were ineffective or less effective in women and older adults.164,165,172 However, these conclusions are based on a faulty reliance on nonstatistically significant findings in post hoc subgroups with relatively small sample sizes (women and older adults).

A retrospective cohort study of Medicare beneficiaries hospitalized with heart failure and LVEF ≤35 percent who were selected for ICD therapy had lower risk-adjusted long-term mortality compared with those who did not receive an ICD.107 This study is susceptible to bias by indication.

## Supplementary Evidence in Excluded Studies

Additional studies that did not meet inclusion criteria for our review supplement our findings. MUSTT was not included in the review, as it was not designed with the specific intention to test ICD therapy versus no ICD therapy for the primary prevention of SCD.41 It compared treatment administered according to a risk stratification algorithm with electrophysiological testing, followed by antiarrhythmic therapy or ICD in those who failed antiarrhythmic therapy versus routine medical management without antiarrhythmic therapy. The risk of cardiac arrest or death from arrhythmia among the patients who received an ICD was significantly lower than that among the patients receiving no antiarrhythmic therapy (adjusted risk ratio [RR] 0.27; 95% CI 0.15, 0.47). The risk of death from all-causes was also significantly lower in patients who received an ICD than in those who received no antiarrhythmic therapy (adjusted RR 0.45; 95% CI 0.32, 0.63). Those receiving medical antiarrhythmic therapy had the highest risk of all-cause mortality and SCD. The trial provided evidence that electrophysiologically guided antiarrhythmic therapy with ICDs reduces the risk of SCD in high-risk patients with CAD, LVEF ≤40 percent, spontaneous and unsustained VT, or sustained tachyarrhythmia induced by programmed stimulation.

Another study in individuals undergoing ICD implantation for primary prevention, MADIT-RIT, did not meet criteria for inclusion in Key Question 1, as it assessed the effect of different programming algorithms to avoid inappropriate ATP or shock therapy.60 However, the trial's data on inappropriate shocks were included in the evidence base for Key Question 2. MADIT-RIT compared three arms with different programming approaches: one with higher rate cutoffs (with a 2.5 second delay before the initiation of therapy at a heart rate of ≥200 beats per minute), one of programming with longer delays (with a 60 second delay at 170 to 199 beats per minute, a 12 second delay at 200 to 249 beats per minute, and a 2.5 second delay at ≥250 beats per minute), and one of conventional programming (with a 2.5 second delay at 170 to 199 beats per minute and a 1.0 second delay at ≥200 beats per minute). The primary outcome measure was time to the first occurrence of inappropriate therapy, either inappropriate ATP or shock, and the secondary outcomes were all-cause mortality and syncope. The trial showed that programming a higher rate cutoff or a longer delay prior to ATP or shock therapy resulted in a lower rate of inappropriate therapy compared with conventional programming. Both interventional arms also had lower mortality for high-rate therapy versus conventional therapy (HR 0.45; 95% CI 0.24, 0.85 for high-rate therapy vs. conventional therapy; and HR 0.56; 95% CI 0.30, 1.02 for delayed therapy versus conventional therapy).

With regard to trials of CRT-D versus ICD, we did not include the Multicenter InSync ICD Randomized Clinical Evaluation trial (MIRACLE ICD),173 the cardiac resynchronization therapy for the treatment of heart failure in patients with intraventricular conduction delay and malignant ventricular tachyarrhythmias trial (CONTAK-CD),88 since these trials were not exclusively primary prevention trials. Although the Cardiac-Resynchronization Therapy in Heart Failure with Narrow QRS Complexes trial (RETHINQ) evaluated CRT-D versus ICD therapy, it was also not included in our review as there were no outcomes of interest.174

## Applicability

The review of the eligibility criteria shows that the findings are applicable to selected individuals in the US and other high-resource countries, in particular individuals with nonischemic or ischemic cardiomyopathy and reduced LVEF (<30 to 35%). For patients with ischemic cardiomyopathy, the finding of benefit from ICD applies to those more than 30 to 40 days after MI and at least 3 months after revascularization.

Compared with the population of primary prevention therapy in the NCDR, the RCT populations of key trials were younger, less often women, and had had a lower burden of comorbidity.169 The subgroup analyses showed no evidence to suggest different efficacy of ICDs in women or older adults. Nevertheless, how representative the trial findings are to the larger eligible Medicare population is an important question. Five out of seven comparative studies in the review provided subgroup data for those over 65 years. They showed that about a third to half of patients were 65 years or older, while the proportion in NCDR is well over 42%.175 One cohort study followed Medicare Beneficiaries (median age 75 years) after primary ICD implantation and found a mortality at 3 years of follow up of 31%.176 This was higher than in the major primary ICD trials SCD-HEFT (mean age 60 years, 3 year mortality 16%) and MADIT-II (mean age 64 years, three year mortality 22%). However, almost half of the Medicare patients did not have previous heart failure hospitalizations and received an ICD on the admission day suggesting they were electively admitted for the procedure. In this subgroup, the mortality of 22% was similar to that of the large trials, despite the difference in mean ages. While most trials did not specify that patients were electively admitted for ICD implantation, this is assumed to be the case.176 This suggests that the trial findings may apply to a sizeable proportion of Medicare patients.

The estimates for adverse events derive from studies with mixed populations (i.e., patients who received ICDs for primary or secondary prevention). One study found no statistically significant difference in the risk of an adverse event or death between patients with ICDs for primary and those with ICDs for secondary prevention, supporting the notion that the rate of procedure-related adverse events, which contribute the majority of adverse events, may be similar across primary and secondary populations.117

## Limitations

Limitations of the evidence base in some RCTs include lack of blinding of outcome assessors of arrhythmia outcomes or SCD, high attrition rates (>20%), or differential rates of attrition and/or crossover between study groups and differences in the control treatments or in the rates of concomitant use of beta blockers between the study groups. Of note, all trials conducted intention-to-treat analyses. Nonsignificant subgroup analyses need to be interpreted in the context of studies likely being underpowered to explore differences in effects across subgroups of interest. At the same time, positive treatment effects within subgroups may represent spurious findings from multiple testing. The quality of the long-term adverse events suffered from a lack of harmonized definitions and systematic ascertainment. This review does not provide a complete assessment of the effectiveness of CRT. The intention of ICD therapy is restoration of normal sinus rhythm in the setting of life-threatening arrhythmias, and the intention of CRT is improvement of functional status and symptoms of heart failure. We did not include heart failure outcomes, which were primary outcomes of interest for the studies comparing CRT-D versus ICD as the focus of our review was prevention of SCD rather than management of heart failure. It is important to point out that study populations in ICD trials and CRT trials have overlapping characteristics but are not exactly the same. Research Gaps

The gaps in our current knowledge are large with regard to knowing which patients should be offered ICD with the expectation of improving meaningful survival. The rates of SCD in the non-ICD trial arms were not consistently reported. Consistent reporting would facilitate an assessment of how the mortality benefit may be correlated with the baseline risk. There is a great need for better risk stratification tools and their validation to better identify those patients who are most likely to benefit from ICD therapy. Some risk scores have been developed in clinical trials and may be used going forward towards reducing the risk of unnecessary ICD implantation. However, since most sudden deaths are not in patients with previously identified risk factors, there is a need explore risk prediction tools that extend beyond currently used trial inclusion criteria.

While it is beyond the scope of the current report, additional risk stratification tools are continually being examined, including measures of autonomic function such as T-wave alternans. This latter modality has been formally studied in a comparative analysis with EP testing in the ABCD (Alternans Before Cardioverter Defibrillator) Trial.177 In addition, advances in magnetic resonance imaging (MRI) or genetic testing may be useful in the future.

Similarly, analyses of subgroups of patients who may particularly benefit (or derive no benefit) from ICD use are needed, especially when the etiology, pathophysiology and competing risks for death differ. To date, the analyses of subgroups are underpowered and inconclusive. A patient-level meta-analysis across major trials may be able to provide the power to adequately evaluate subgroups. Future trials should focus on elderly, women, who constitute only a minority in clinical ICD trials, and on patients with chronic kidney disease. We found no eligible studies in children, pointing to this group also requiring future study.

A research gap also exists in the area of primary prevention of SCD in familial or inherited conditions as well as less common cardiomyopathies including but not limited to long-QT syndrome, Brugada syndrome, catecholaminergic polymorphic VT, hypertrophic cardiomyopathy, arrhythmogenic right ventricular dysplasia, cardiac sarcoidosis, and left ventricle noncompaction. These disease states are less prevalent than ischemic cardiomyopathy and nonischemic dilated cardiomyopathy and were, in large part, implicitly or explicitly excluded from the studies in this review. In particular, patients with channelopathies have structurally normal hearts (i.e., those with normal LVEFs) but nonetheless, may have an elevated risk of SCD. Patients with hypertrophic cardiomyopathy generally have hyperdynamic ventricles until they reach the end stage of the disease process. Thus, many or most of these patients would have also been excluded in the RCTs to date. While there are research gaps for these patient groups, the low prevalence of some of these diseases presents challenges for conducting RCTs. The NCDR ICD database provides an opportunity to track these patients and describe their outcomes.

As mentioned above, the intent of this review was to address sudden cardiac death outcomes rather than heart failure outcomes. Since one of the primary goals of chronic resynchronization therapy is the improvement of heart failure, this issue was not completely addressed. Thus, a comparative effectiveness review of CRT warrants a separate review in order to address outcomes related to heart failure and mortality. In order to be comprehensive, CRT-P and CRT-D studies have to be included.

While there is robust information on adverse events immediately post implantation in the hospital, there are also large gaps in the knowledge about adverse events after the hospitalization for implantation and the impact on patient reported outcomes. This includes information on likelihood of lead complications needing revision, likelihood of both appropriate and inappropriate shocks, resulting distress from ICD shocks and impact on QoL. Another crucial issue that is uncertain is the impact of ICD on the quality of death, and the challenge to approach ICD inactivation to avoid undesired shocks at the end of life.

In an era of fast-paced technological advances, it is imperative to critically reevaluate the incremental net benefit and cost of evolving medical and device therapies. On September 28, 2012, the US Food and Drug Administration approved the first subcutaneous ICD, which incorporates a generator and a lead that is implanted below the skin along the bottom of the rib cage and breast bone, removing the need for fluoroscopic guidance and direct vascular or cardiac access. Data in support of the approval were from a 33-center trial involving 321 patients who underwent ICD implantation or were undergoing replacement for a transvenous ICD.178 A postmarket study will follow 1,616 patients for 5 years.

Evolution in programming algorithms may also alter the benefits harms balance.179 As discussed above, MADIT-RIT showed mortality benefit for programming algorithms which may be additive to the benefit of an ICD alone.

## Conclusions

There is a high strength of evidence that ICD therapy for primary prevention of SCD, versus no ICD therapy, shows benefit with regard to mortality and SCD in selected patients with reduced LVEF and ischemic or nonischemic cardiomyopathy. There is low strength of evidence that the risk of all-cause mortality is similar for patients who receive CRT-Ds versus ICD alone for primary prevention. A high strength of evidence shows overall early in-hospital adverse event rates of approximately 3 percent and serious adverse event rates of approximately 1 percent. Low strength of evidence shows variable late adverse events. Moderate strength of evidence shows inappropriate shocks are experienced by 3 to 21 percent of patients over 1 and 5 years of followup.