# Supplemental Tables

Appendix Table 1 Baseline data

Study Author, Year PMID | Intervention (Control) | Baseline characteristics Intervention (Control)
Study Author, Year PMID | Intervention (Control) | Age, y (mean or median) | %Male | %LVEF | %NYHA class | %DM | QRS interval
ICD vs. no ICD
AMIOVIRT Strickberger, 2003 12767651 | ICD (Amiodarone) | 58 (60) | 67 (74) | 22 (23) | Class I: 18 (13); Class II:64 (63); Class III: 16 (24) | 31 (36) | nd
CABG-Patch Bigger, 1997 9371853 | ICD (No ICD) | 64 (63) | 87 (82) | 27 (27) | Class II or III: 71 (74) | 36 (40) | QRS complex >100 msec: 71 (74)
CAT Bansch, 2002 11914254 | ICD (Control) | 52 (52) | 86 (74) | 24 (25) | Class II: 67 (64); Class III: 33 (36) | NR | “Abnormal”: 27 (45)
Chan, 2009 20031808 | ICD (No ICD) | 66 (66) | 80 (75) | 26 (28) | nd | 35 (37) | %QRS interval >120 msec: 32 (21)
COMPANION Bristow, 2004 15152059 | ICD + CRT (No ICD) | 66 (68) | 67 (69) | 22 (22) | Class III: 86 (82) | 41 (45) | 160 (158)
DEFINITE Kadish, 2004 15152060 | ICD (No ICD) | 58 (58) | 73 (70) | 21 (22) | Class I: 25 (18); Class II: 54 (61); Class III: 21 (21) | 23 (23) | 115 (116)
Hohnloser, 2004 15590950 DINAMIT | ICD (No ICD) | 62 (62) | 76 (77) | 28 (28) | Class I: 14 (12); Class II:31 (59); Class III: 26 (29) | 31 (29) | 107 (105)
Fonarow, 2000 10760339 | ICD (Control) | 49 (48) | 68 (58) | 21 (21) | Class III: 48 (49); Class IV: 52 (51) | NR | nd
IRIS Steinbeck, 2009 19812399 | ICD (No ICD) | 63 (62) | 78 (76) | NR | At hospital discharge post-MI, the NYHA Class could be assessed in 885 of the surviving patients and was judged to be Class I in 247 patients (28%), Class II in 531 (60%), and Class III in 106 (12%); the Class changed to IV in 1 patient (0.1%). | 37 (30) | nd
MADIT Moss, 1996 8960472 | ICD (No ICD) | 62 (64) | 97 (91) | 27 (25) | Class II or III: 63 (67) | 7 (5) | nd
MADIT II Moss, 2002 11907286 | ICD (No ICD) | 64 (65) | 84 (85) | 23 (23) | Class I: 35 (39); Class II:35 (34); Class III: 25 (23); Class IV: 5 (4) | 33 (38) | %QRS interval ≥120 msec: 50 (51)
Mezu, 2011 21640321 | ICD (No ICD) | 82 (86) | 77 (67) | 24 (27) | Class III or IV: 44 (72) | 34 (63) | nd
OPTIMIZE-HF and GWTG-H Hernandez, 2010 20009044 | ICD (No ICD) | 74 (75) | 74 (58) | 23 (25) | nd | 37 (44) | nd
SCD-HeFT Bardy, 2005 15659722 | ICD (No ICD/placebo) | 60 (60) | 77 (76) | Median: 24 (25) | nd | 31 (29) | nd
ICD vs. CRT-D
Diab, 2011 21700757 | ICD (CRT-D) | 65 (67) | 90 (88) | 27 (25) | Class III: 89 (88) Mean: 3.2 (3.1) | NR | 142 (134)
MADIT-CRT Moss, 2009 19723701 | ICD (CRT-D) | 64 (65) | 76 (75) | 24 (24) | Class I (all ischemic): 16 (14); Class II (ischemic): 39 (41); Class II (nonischemic): 45 (45) | 31 (30) | %QRS duration ≥150 msec: 65 (64)
MENDMI Chung, 2010 20852059 | ICD (CRT-D) | 55 (58) | 68 (81) | 29 (28) | Class I: 16 (17); Class II: 34 (29); Class III: 34 (38); Unknown: 16 (17) | 11 (5) | 91 (86)
RAFT Tang, 2010 21073365 | ICD (CRT-D) | 66 (66) | 81 (85) | 23 (23) | Class II: 81 (79); Class III: 19(21) | 35 (33) | Intrinsic: 158 (157); Paced: 210 (207)

AMIOVERT=Amiodarone versus Implantable Cardioverter-Defibrillator Randomized Trial, CABG-Patch=Coronary Artery Bypass Graft Patch, CAT=Cardiomyopathy Trial, COMPANION=Comparison of Medical Therapy, Pacing and Defibrillation in Heart Failure, CRT-D=cardiac resynchronization therapy defibrillator, DEFINITE=Defibrillators in Nonischemic Cardiomyopathy Treatment Evaluation, DINAMIT=Defibrillator in Acute Myocardial Infarction Trial, DM=diabetes, GWTG-HF= Get With the Guidelines-Heart Failure, ICD=implantable cardiac defibrillator, IRIS=Immediate Risk Stratification Improves Survival, LVEF=left ventricular ejection fraction, MADIT=Multicenter Automatic Defibrillator Implantation Trial, MADIT-CRT=Multicenter Automatic Defibrillator Implantation Trial with Cardiac Resynchronization Therapy, MENDMI=Prevention of Myocardial Enlargement and Dilation Post Myocardial Infarction Study, MI= myocardial infarction, msec, millisecond, nd=not documented, NYHA=New York Heart Association, OPTIMIZE-HF=Organized Program to Initiate Lifesaving Treatment in Hospitalized Patients with Heart Failure, SCD-HeFT= Sudden Cardiac Death in Heart Failure Trial, VT=ventricular tachycardia

Appendix Table 2 Concomitant medications

Study Author, Year PMID | Intervention (Control) | Medications Intervention (Control)
Study Author, Year PMID | Intervention (Control) | %Antiarrhythmic drug Class I | %Antiarrhythmic drug Class III | %Beta blocker | %ACEi or ARB | Control (Verbatim)
ICD vs. no ICD
AMIOVIRT Strickberger, 2003 12767651 | ICD (Amiodarone) | nd | Amiodarone: 0 (100) | Last follow-up: 53 (50) | Last follow-up: 90 (81) | Subjects were randomly assigned to receive either amiodarone or an ICD.
CABG-Patch Bigger, 1997 9371853 | ICD (No ICD) | 17 (12) | Amiodarone: 4 (3); Sotalol: 1 (0.2) | 18 (24) | ACEi: 55 (54) | Patients were randomly assigned to the defibrillator or control group within randomly permuted blocks. The trial protocol prohibited the use of antiarrhythmic drugs for asymptomatic ventricular arrhythmia and specified that patients without contraindications should be treated with aspirin.
CAT Bansch, 2002 11914254 | ICD (Control) | nd | nd | 4 (4) | ACEi: 94 (98) | Patients with recent onset of DCM (9 months) and an ejection fraction 30% were randomly assigned to the implantation of an ICD or control.
Chan, 2009 20031808 | ICD (No ICD) | 1 (0.4) | Class III: 8 (8) | 86 (83) | 86 (86) | The study cohort comprised 965 patients (751 [77.8%] ischemic; 214 [22.2%] nonischemic), of whom 494 (51.2%) received ICDs.
COMPANION Bristow, 2004 15152059 | ICD + CRT (No ICD) | nd | nd | 68 (66) | 90 (89) | Eligible patients who provided written informed consent were randomly assigned in a 1:2:2 ratio to treatment with protocol-mandated optimal pharmacologic therapy alone, optimal pharmacologic therapy plus cardiac resynchronization therapy with a pacemaker, or optimal pharmacologic therapy plus cardiac-resynchronization therapy with a pacemaker–defibrillator. The pharmacologic therapy used in all groups consisted of diuretics (unless they were not needed), ACEi (unless they were not tolerated, where-upon ARBs could be substituted), beta-blockers (unless they were not tolerated or were contraindicated), and spironolactone (unless it was not tolerated). Digoxin and other medications used to treat heart failure could be given at the investigator's discretion.
DEFINITE Kadish, 2004 15152060 | ICD (No ICD) | nd | Amiodarone: 4 (7) | 86 (84) | ACEi: 84 (87); ARB: 14 (9) | Patients were randomly assigned to receive either standard oral medical therapy for heart failure or standard oral medical therapy plus an ICD. All patients received ACEi unless they were contraindicated. Patients who were unable to tolerate ACE inhibitors received hydralazine or nitrates or ARBs. In addition, beta-blocker therapy was required unless patients were unable to tolerate it. Carvedilol was the beta-blocker of choice on the basis of data available when the study was designed. The doses of ACEi and beta-blockers were adjusted to the levels recommended for patients with heart failure or to the highest tolerated doses. Digoxin and diuretics were used when necessary to manage clinical symptoms. The use of antiarrhythmic drugs such as amiodarone was discouraged. However, it was recognized that some patients had symptomatic atrial fibrillation or supraventricular arrhythmias requiring treatment with amiodarone, and these conditions did not constitute exclusion criteria. No other antiarrhythmic drugs were used.
DINAMIT Hohnloser, 2004 15590950 | ICD (No ICD) | nd | nd | 87 (87) | 95 (94) | Patients were randomly assigned in a 1:1 ratio either to receive an ICD (the ICD group) or not to receive an ICD (the control group). The study protocol mandated that patients receive the best conventional medical therapy. Investigators were encouraged to treat all study patients with ACEi, beta-blockers, aspirin, and lipid-lowering drugs, as appropriate.
Fonarow, 2000 10760339 | ICD (Control) | 4 (12) | Amiodarone: 40 (36) | 0 (5) | ACEi: 83 (74) | Of the 147 patients, 122 were treated with conventional medical therapy. Patients with atrial fibrillation or frequent nonsustained VT received low-dose amiodarone (200 mg/day) after varied loading protocols. Type I antiarrhythmic agents for nonsustained VT or atrial fibrillation were generally discontinued.
IRIS Steinbeck, 2009 19812399 | ICD (No ICD) | “Anti-arrhythmic drugs (mainly amiodarone): 13 (17) | “Anti-arrhythmic drugs (mainly amiodarone): 13 (17) | 89 (86) | 82 (82) | The remaining 898 patients (86% of whom were still in the hospital) were randomly assigned to a study treatment — 445 to receive an ICD and 453 to receive medical therapy alone — at a mean (±SD) of 13±7 days after infarction.
MADIT Moss, 1996 8960472 | ICD (No ICD) | At 1 mo: 12 (10) | At 1 mo: Amiodarone: 2 (74); Sotalol: 1 (7); Sotatol and beta-blockers: 27 (15) | At 1 mo: 26 (8) | At 1 mo: ACEi: 60 (55) | The choice of conventional medical therapy, including the decision whether to use antiarrhythmic medications, was left to the patient's attending physician. Antiarrhythmic drugs approved and released by the FDA could be administered to patients in either group.
MADIT II Moss, 2002 11907286 | ICD (No ICD) | 3 (2) | Amiodarone: 13 (10) | 70 (70) | ACEi: 68 (72) | The patients were randomly assigned in a 3:2 ratio to receive either an implantable defibrillator or conventional medical therapy. The appropriate use of beta-blockers, ACEi, and lipid-lowering drugs was strongly encouraged in both study groups.
Mezu, 2011 21640321 | ICD (No ICD) | I and III: 9 (22) | I and III: 9 (22) | 70 (61) | ACEi: 77 (65) | We identified all patients who received an ICD at our institution from January 2000 through December 2008 and were 80 years of age at the time of their ICD implantation.
OPTIMIZE-HF and GWTG-HF Hernandez, 2010 20009044 | ICD (No ICD) | nd | nd | 84 (78) | 78 (72) | We identified patients with heart failure who were aged 65 years or older and were eligible for an ICD, had left ventricular ejection fraction of 35% or less, and were discharged alive from hospitals participating in the Organized Program to Initiate Lifesaving Treatment in Hospitalized Patients With Heart Failure and the Get With the Guidelines–Heart Failure quality-improvement programs during the period January 1, 2003, through December 31, 2006. We matched the patients to Medicare claims to examine long-term outcomes.
SCD-HeFT Bardy, 2005 15659722 | ICD (No ICD/placebo) | nd | nd | At enrollment: 69 (69) | At enrollment: 94 (97) | From September 16, 1997, to July 18, 2001, we randomly assigned 2521 patients in equal proportions to receive placebo, amiodarone, or a single-chamber ICD programmed to shock-only mode.
ICD vs. CRT-D
Diab, 2011 21700757 | ICD (CRT-D) | nd | nd | 73 (71) | 100 (98) | All patients underwent a device implantation procedure but were blinded to whether they received a CRT-D or an ICD device.
MADIT-CRT Moss, 2009 19723701 | ICD (CRT-D) | 0.4 (1) | Amiodarone: 7 (7) | 93 (93) | ACEi: 77 (77); ARB: 20 (21) | The patients were randomly assigned in a 3:2 ratio to receive either CRT with an ICD (CRT–ICD group) or only an ICD (ICD-only group) and were stratified according to clinical center and ischemic status with the use of an algorithm that ensured near balance in each stratum.
MENDMI Chung, 2010 20852059 | ICD (CRT-D) | nd | nd | 94 (94) | 94 (88) | Eligible patients were randomized 1:1 in blocks of 4 stratified per center to therapy CRT-D or control (ICD) between 3 and 14 days of their presenting MI.
RAFT Tang, 2010 21073365 | ICD (CRT-D) | nd | nd | 89 (90) | 97 (96) | Eligible patients were randomly assigned in a 1:1 ratio to receive an ICD or an ICD with CRT and were stratified according to clinical center, atrial rhythm (atrial fibrillation or flutter or sinus–atrial pacing), and a planned implantation of a single- or dual-chamber ICD.

ACEi=angiotensin-converting-enzyme inhibitor, ARB=angiotensin receptor blockers, CRT-D=cardiac resynchronization therapy defibrillator, ICD=implantable cardiac defibrillator, nd=not documented, VT=ventricular tachycardia

For study names, see Appendix Table 1.

Appendix Table 3 ICD vs. No ICD: Results for all-cause mortality at longest follow-up

Study Author, Year PMID | Outcome name | Timepoint | Outcome description | Intervention (Control) | Events Intervention (Control) | N analyzed Intervention (Control) | Metric | Results (95% CI) | p-value between arms
≥4 year
MADIT II Barsheshet, 2011 210448997 | Death, all-cause longest follow-up | 8 y | nd | ICD (No ICD) | ∼44%^1^ (∼55%) | 567 (490) | Adjusted HR | 0.55 (0.46-0.67) | <0.001
CAT Bansch, 2002 11914254 | Death, all-cause longest follow-up | 5 y | nd | ICD (No ICD) | 13 (17) | 50 (54) | nd | nd | nd
DEFINITE Kadish, 2004 15152060 | Death, all-cause longest follow-up | 5 y | nd | ICD (No ICD) | 28 (40) | 229 (229) | Unadjusted HR^2^ | 0.65 (0.40-1.06) | 0.08
MADIT Moss, 1996 8960472 | Death, all-cause longest follow-up | 5 y | nd | ICD (No ICD) | 15 (39) | 95 (101) | HR | 0.46 (0.26-0.82) | 0.009
SCD-HeFT Bardy, 2005 15659722 | Death, all-cause longest follow-up | 5 y | nd | ICD (No ICD/placebo) | 182 (240) | 829 (845) | nd | nd | nd
MADIT II Moss, 2002 11907286 | Death, all-cause longest follow-up | 4 y | nd | ICD (No ICD) | 105 (97) | 742 (490) | HR | 0.69 (0.51-0.93) | 0.016
2-3 y
Chan, 2009 20031808 | Death, all-cause longest follow-up | 3 y | Death at 34 ± 16 mo in ICD arm; Death at 33 ± 16 mo in No ICD arm | ICD (No ICD) | 102 (115) | 494 (471) | Adjusted HR | 0.69 (0.50-0.96) | 0.03
OPTIMIZE-HF and GWTG-HF Hernandez, 2010 20009044 | Death, all-cause longest follow-up | 3 y | Death at 3 y | ICD (No ICD) | 101 (1771) | 376 (4,309) | Inverse-weighted HR (control for meds) | 0.71 (0.56-0.91)^3^ | <0.001
AMIOVIRT Strickberger, 2003 12767651 | Death, all-cause longest follow-up | 2 y | Duration of follow-up 2.2 y ion ICD arm and 1.8 y in Amiodarone arm | ICD (Amiodarone) | 6 (7) | 51 (52) | nd | nd | 0.8
DEFINITE Kadish, 2004 15152060 | Death, all-cause longest follow-up | 2 y | nd | ICD (No ICD) | 7.9% (14.1%) | 229 (229) | nd | nd | nd
Fonarow, 2000 10760339 | Death, all-cause longest follow-up | 2 y | nd | ICD (No ICD) | 2 (31) | 25 (122) | nd | nd | nd
MADIT II Moss, 2002 11907286 | Death, all-cause longest follow-up | 2 y | nd | ICD (No ICD) | ∼15%^4^ (∼31%) | 742 (490) | % difference | -28% (-46%, 4%) | NS
Mezu, 2011 21640321 | Death, all-cause longest follow-up | 2 y | Death during study | ICD (No ICD) | 58 (35) | 99 (53) | nd | nd | nd
OPTIMIZE-HF and GWTG-HF Hernandez, 2010 20009044 | Death, all-cause longest follow-up | 2 y | Death at 2 y | ICD (No ICD) | 90 (1550) | 376 (4,309) | nd | nd | <0.001
CABG-Patch Bigger, 1997 9371853 | Death, all-cause longest follow-up | 3 y | Death at 32 ± 16 mo | ICD (No ICD) | 101 (95) | 446 (454) | HR, Cox adjusted for 10 prespecified covariates | 1.03 (0.75-1.41) | NS
DINAMIT Hohnloser, 2004 15590950 | Death, all-cause longest follow-up | 3 y | All cause mortality at 30 ± 13 mo | ICD (No ICD) | 62 (58) | 332 (342) | HR | 1.08 (0.76-1.55) | 0.66
IRIS Steinbeck, 2009 19812399 | Death, all-cause longest follow-up | 3 y | nd | ICD (No ICD) | 116 (117) | 445 (453) | HR | 1.04 (0.81-1.35) | 0.15
IRIS Steinbeck, 2009 19812399 | Death, all-cause longest follow-up | 2 y | nd | ICD (No ICD) | 15.4% (18.2%) | 445 (453) | nd | nd | nd
1 y
AMIOVIRT Strickberger, 2003 12767651 | Death, all-cause longest follow-up | 1 y | nd | ICD (Amiodarone) | 96% (90%) | 51 (52) | nd | nd | nd
CAT Bansch, 2002 11914254 | Death, all-cause longest follow-up | 1 y | nd | ICD (No ICD) | 4 (2) | 50 (54) | nd | nd | nd
COMPANION Bristow, 2004 15152059 | Death, all-cause longest follow-up | 1 y | Death from any cause | ICD + CRT (No ICD) | 105 (77) | 595 (308) | HR | 0.76 (0.58-1.01) | 0.059 (Adjusted 0.06)
DEFINITE Kadish, 2004 15152060 | Death, all-cause longest follow-up | 1 y | nd | ICD (No ICD) | 2.6% (6.2%) | 229 (229) | nd | nd | nd
Fonarow, 2000 10760339 | Death, all-cause longest follow-up | 1 y | nd | ICD (Control) | 6.7% (24.5%) | 25 (122) | nd | nd | nd
MADIT II Moss, 2002 11907286 | Death, all-cause longest follow-up | 1 y | nd | ICD (No ICD) | ∼8%^5^ (∼10%) | 742 (490) | % difference | -12% (-40%, 27%) | NS
Mezu, 2011 21640321 | Death, all-cause longest follow-up | 1 y | Death at 1 y | ICD (No ICD) | 72% (52%) | 99 (53) | Adjusted HR^6^ | 0.78 (0.44-1.30) | 0.312
OPTIMIZE-HF and GWTG-HF Hernandez, 2010 20009044 | Death, all-cause longest follow-up | 1 y | Death at 1 y | ICD (No ICD) | 65 (1102) | 376 (4,309) | nd | nd | <0.001
IRIS Steinbeck, 2009 19812399 | Death, all-cause longest follow-up | 1 y | nd | ICD (No ICD) | 10.6% (12.5%) | 445 (453) | nd | nd | nd

1 Estimated from figure

2 Adjusted model “unchanged” at 0.65 but CI not reported

3 Unadjusted HR 0.67 (0.52-0.87)

4 Estimated from figure

5 Estimated from figure

6 Adjusted for age, Charlson comorbidity index, LVEF, GFR

CI=confidence interval, HR=hazards ratio, ICD=implantable cardiac defibrillator, mo=month, nd=not documented, NS=not significant, y=year

For study names, see Appendix Table 1.

Appendix Table 4 ICD plus CRT versus ICD alone: Results for all-cause mortality at longest followup

Study Author, Year PMID | Outcome name | Timepoint | Outcome description | Intervention (Control) | Events Intervention (Control) | N analyzed Intervention (Control) | Metric | Results (95% CI) | p-value between arms
≥4 year
MADIT-CRT Moss, 2009 19723701 | Death, all-cause longest followup | 5 y | nd | CRT-D (ICD) | 74 (53) | nd | HR | 1.00 (0.69-1.44) | 0.99
3 years
RAFT Tang, 2010 21073365 | Death, all-cause longest followup | 3 y | Death from any cause | CRT-D (ICD) | 186 (236) | 894 (904) | HR | 0.75 (0.62-0.91) | 0.003
1 y
Diab, 2011 21700757 | Death, all-cause longest followup | 1 y | Mortality | CRT-D (ICD) | 0 (2) | nd | nd | nd | nd
MENDMI Chung 2010 20852059 | Death, all-cause longest followup | 1 y | All–cause mortality | CRT-D (ICD) | 1 (1) | 42 (38) | nd | nd | 1.00

CI=confidence interval, CRT-D=cardiac resynchronization therapy defibrillator, HR=hazards ratio, nd=not documented, y=year

For study names, see Appendix Table 1.

Appendix Table 5 Subgroup analyses of ICD vs. no ICD for all-cause death

Study, Author, Year, PMID | Subgroups HR/RR (95% CI) | | | | P Interaction
Age
MADIT, Moss, 1996, 8960472 | Continuous: | nd | | | P>0.2
CABG-Patch, Bigger, 1997, 9371853 | Continuous: | nd | | | NS
MADIT II, Moss, 2002, 11907286 | <60 y: ≥70 y: | 0.5 (0.2, 0.9) 0.6 (0.45, 0.95) | 60-69 y: | 0.8 (0.5, 1.3) | NS
DINAMIT, Hohnloser, 2004, 15590950 | <60 y: | 0.9 (0.4, 1.9) | ≥60 y: | 1.2 (0.8, 1.9) | P=0.46
Chan, 2009, 20031808^*^ | <65 y: ≥75 y: | 0.74 (0.43,1.28) 0.59 (0.39, 0.90) | 65-74 y: | 0.76 (0.45, 1.29) | P=0.43
COMPANION, Bristow, 2004, 15152059 | ≤65 y: | 0.6 (0.3, 0.95) | >65 y: | 0.7 (0.5, 1.0) | nd
SCD-HeFT, Bardy 2005 15659722 | <65 y: | 0.68 (0.50, 0.93)^†^ | ≥65 y: | 0.86 (0.62, 1.18)^†^ | nd
DEFINITE, Kadish, 2004, 15152060 | <65y; | 0.7 (0.3, 1.4) | ≥65 y: | 0.6 (0.3, 1.2) | NS
IRIS, Steinbeck, 2009, 19812399 | <65 y: | 0.95 (0.6, 1.5) | ≥65 y: | 1.05 (0.8, 1.5) | P=0.73
OPTIMIZE-HF and GWTG-H, Hernandez, 2010, 20009044^*^ | 65-74 y: | 0.65 (0.47, 0.89) | 75-84 y: | 0.80 (0.62, 1.03) | P=0.31
Sex
CABG-Patch, Bigger, 1997, 9371853 | Female: | nd | Male: | nd | NS
COMPANION, Bristow, 2004, 15152059 | | 0.6 (0.3, 1.1) | | 0.65 (0.4, 0.9) | nd
DEFINITE, Kadish, 2004, 15152060 | | 1.1 (0.5-2.6) | | 0.49 (0.27, 0.90) | NS
DINAMIT, Hohnloser, 2004, 15590950 | | 1.0 (0.5-2.1) | | 1.1 (0.7-1.7) | P=0.82
IRIS, Steinbeck, 2009, 19812399 | | 1.0 (0.6-1.7) | | 1.1 (0.8-1.5) | P=0.85
MADIT II Moss, 2002, 11907286 | | 0.6 (0.3-1.1) | | 0.7 (0.5-0.9) | NS
MADIT, Moss, 1996, 8960472 | | nd | | nd | P>0.2
OPTIMIZE-HF and GWTG-H, Hernandez, 2010, 20009044^*^ | | 0.58 (0.41,0.83) | | 0.80 (0.63,1.01) | P=0.15
SCD-HeFT, Russo 2008 18373605 | | 0.90 (0.56, 1.43)^†^ | | 0.71 (0.57, 0.88)^†^ | P=0.54^‡^
Race/Ethnicity
SCD-HeFT, Mitchell, 2008, 18294487 Bardy 2005 15659722 | AA: | 0.65 (0.43, 0.99)^†^ | White: | 0.73 (0.58, 0.90)^†^ | P=0.53
SCD-HeFT, Mitchell, 2008, 18294487 Bardy 2005 15659722 | Non-white: | 0.75 (0.48, 1.17)^†^ | White: | 0.78 (0.61, 1.00)^†^ | nd
NYHA Class
CABG-Patch, Bigger, 1997, 9371853 | | nd | | | NS
COMPANION, Bristow, 2004, 15152059 | III: | 0.6 (0.4, 0.97) | IV: | 0.6 (0.4, 1.0) | nd
DEFINITE, Kadish, 2004, 15152060 | I: III: | 0.5 (0.2, 1.5) 0.37 (0.15, 0.90) | II: | 1.0 (0.5, 2.2) | NS
DINAMIT, Hohnloser, 2004, 15590950 | 0-II: | 1.1 (0.7, 1.7) | III: | 1.0 (0.5, 2.3) | P=0.87
MADIT, Moss, 1996, 8960472 | | nd | | | P>0.2
MADIT II Moss, 2002, 11907286 | I | 0.6 (0.5, 0.9) | II-IV: | 0.7 (0.45, 1.0) | NS
SCD-HeFT, Bardy 2005 15659722 | II: | 0.54 (0.40, 0.74)^†^ | III: | 1.16 (0.84, 1.61)^†^ | P<0.001
Heart Failure
CABG-Patch, Bigger, 1997, 9371853 | Yes: | nd | No: | nd | NS
Chan, 2009, 20031808^*^ | | 0.69 (0.50, 0.93) | | 0.70 (0.35, 1.41) | P=0.59
MADIT, Moss, 1996, 8960472 | | nd | | nd | P>0.2
IRIS, Steinbeck, 2009, 19812399 | | 1.0 (0.7, 1.4) | | 1.2 (0.8, 1.8) | P=0.56
Time Since Heart Failure Diagnosis
DEFINITE, Kadish, 2006, 16781376 | ≤3 mo: | 0.38 (0.14, 1.000) | >3 mo: | 0.80 (0.46,1.41) | P=0.19
DEFINITE, Kadish, 2006, 16781376 | ≤9 mo: | 0.46 (0.216, 0.986) | >9 mo: | 0.86 (0.46,1.61) | P=0.22
LVEF
CABG-Patch, Bigger, 1997, 9371853 | | nd | | | NS
Chan, 2009, 20031808^*^ | ≤25%: | 0.73 (0.51, 1.04) | 26-35%: | 0.59 (0.37, 0.93) | P=0.61
COMPANION, Bristow, 2004, 15152059 | ≤20: | 0.6 (0.4, 0.9) | 20-35%: | 0.7 (0.4, 1.1) | nd
DEFINITE, Kadish, 2004, 15152060 | <20%: | 0.9 (0.4, 2.0) | 20-36%: | 0.5 (0.3,0.95) | NS
DINAMIT, Hohnloser, 2004, 15590950 | <26%: | 1.5 (0.8, 2.7) | 26-35%: | 0.85 (0.5, 1.5) | P=0.16
OPTIMIZE-HF and GWTG-H, Hernandez, 2010, 20009044^*^ | ≤30%: | 0.76 (0.59, 0.98)^§^ | All patients: | 0.71 (0.56, 0.91)^§^ | NA
MADIT, Moss, 1996, 8960472 | Continuous: | nd | | | P>0.2
MADIT II, Moss, 2002, 11907286 | ≤25%: | 0.6 (0.5, 0.9) | | 25-30% 0.7 (0.4, 1.2) | NS
SCD-HeFT, Bardy 2005 15659722 | ≤30%: | 0.73 (0.57, 0.92)^†^ | 30-35%: | 1.08 (0.57, 2.07)^†^ | nd
LBBB
COMPANION, Bristow, 2004, 15152059 | LBBB: | 0.5 (0.4, 0.8) | Other: | 0.9 (0.5, 1.6) | nd
MADIT, Moss, 1996, 8960472 | LBBB: | nd | No LBBB: | nd | P>0.2
MADIT II, Moss, 2002, 11907286 | LBBB: | nd | No LBBB: | nd | NS
QRS Duration
CABG-Patch, Bigger, 1997, 9371853 | ≤100 msec: | nd | >100 msec: | nd | NS
COMPANION, Bristow, 2004, 15152059 | ≤147 msec: 168 msec: | 0.8 (0.4, 1.3) 0.5 (0.3, 0.97) | 148-168 msec: | 0.6 (0.3, 1.0) | nd
DEFINITE, Kadish, 2004, 15152060 | <120 msec: | 0.75 (0.4, 1.5) | ≥120 msec: | 0.5 (0.2, 1.1) | NS
DINAMIT, Hohnloser, 2004, 15590950 | <120 msec: | 0.85 (0.5, 1.4) | ≥120 msec: | 1.5 (0.8, 2.9) | P=0.13
MADIT II, Moss, 2002, 11907286 | <120 msec: ≥150 msec: | 0.7 (0.5, 1.2) 0.5 (0.3, 0.9) | 120-150 msec: | 0.6 (0.4, 1.1) | NS
SCD-HeFT, Bardy 2005 15659722 | <120 msec: | 0.84 (0.62, 1.14)^†^ | ≥120 msec: | 0.67 (0.49, 0.93)^†^ | nd
Heart Disease
COMPANION, Bristow, 2004, 15152059 | Ischemic: | 0.73 (0.52, 1.04) | Non-ischemic: | 0.5 (0.29, 0.88) | NS
Time Since Myocardial Infarction
SCD-HeFT, Piccini, 2011, 21109025 | <18 mo: 52-111 mo: | 0.7 (0.37, 1.31)^†^ 1.47 (0.75, 2.87)^†^ | 18-51 mo: >111 mo: | 0.54 (0.3, 0.98)^†^ 0.75 (0.44, 1.29)^†^ | P=0.33
MADIT, Moss, 1996, 8960472 | <6 mo: | nd | ≥6 mo: | nd | P>0.2
MADIT II, Moss, 2002, 11907286 | <6 mo: | nd | ≥6 mo: | nd | NS
MADIT II, Wilber, 2004, 14993128 | <18 mo: | 0.97 (0.51, 1.81) | ≥18 mo: | 0.55 (0.39, 0.78) | P=0.27
MADIT II, Wilber, 2004, 14993128 | 18-59 mo ≥120 mo: | 0.52 (0.26, 1.05) 0.62 (0.36, 1.08) | 60-119 mo | 0.50 (0.26, 0.91) | nd
Prior Coronary Revasc
MADIT, Moss, 1996, 8960472 | CR: | nd | No CR: | nd | P>0.2
SCD-HeFT, Al-Khatib 2008 18479330 | CABG: | 0.87 (0.62, 1.22) | No CABG: | 0.66 (0.47, 0.94) | P=0.39
SCD-HeFT, Al-Khatib 2008 18479330 | PCI: | 0.66 (0.36, 1.22) | No PCI: | 0.82 (0.53, 1.29) | P=0.93
Time Since Coronary Revasc
MADIT II, Goldenberg, 2006, 16682305 | ≤6 mo: | 1.19 (0.40, 3.54) | >6 mo: | 0.64 (0.45, 0.90) | P=0.29
MADIT II, Goldenberg, 2006, 16682305 | 7-60 mo: | 0.55 (0.31, 0.97) | >60 mo | 0.67 (0.43, 1.03) | nd
SCD-HeFT, Al-Khatib 2008 18479330 | CABG ≤2 y: | 1.40 (0.61, 3.24) | CABG >2 y: | 0.71 (0.49, 1.04) | P=0.09
SCD-HeFT, Al-Khatib 2008 18479330 | Time since PCI: | nd | | | P=0.51
Diabetes Mellitus
CABG-Patch, Bigger, 1997, 9371853 | Yes: | nd | No: | nd | NS
Chan, 2009, 20031808^*^ | | 0.68 (0.45, 1.03) | | 0.69 (0.48, 1.01) | P=0.95
DINAMIT, Hohnloser, 2004, 15590950 | | 0.9 (0.5, 1.5) | | 1.2 (0.8, 2.0) | P=0.38
IRIS, Steinbeck, 2009, 19812399 | | nd | | nd | NS
MADIT II, Moss, 2002, 11907286 | | nd | | nd | NS
SCD-HeFT, Bardy 2005 15659722 | | 0.95 (0.68, 1.33)^†^ | | 0.67 (0.50, 0.90)^†^ | nd
Blood Urea Nitrogen
MADIT, Moss, 1996, 8960472 | ≤25 mg/dL: | nd | >25 mg/dL: | nd | P>0.2
MADIT II Moss, 2002, 11907286 | ≤25 mg/dL: | nd | >25 mg/dL: | nd | NS
Kidney Disease
Chan, 2009, 20031808^*^ | Kidney failure: | 0.52 (0.11, 2.48) | No kidney failure: | 0.70 (0.53, 0.94) | P=0.21
MADIT II, Goldenberg, 2006, 16893702 | eGFR ≥35: | 1.09 (0.49, 2.43) | eGFR <35: | 0.68 (0.50, 0.93) | P=0.29
MADIT II, Goldenberg, 2006, 16893702 | eGFR 35-59: | 0.74 (0.48, 1.15) | eGFR ≥60: | 0.66 (0.43, 1.02) | nd

A = African American, CABG = coronary artery bypass graft, CI =confidence interval, CR = coronary revascularization, eGFR = estimated glomerular filtration rate (in mL/min/m^2^, HR = hazard ratio, ICD = implantable cardiac defibrillator, LBBB = left bundle branch block, LVEF = left ventricular ejection fraction, mo = month, NA = not applicable, nd =no data, NS = Not statistically significant (no P-value documented), PCI = percutaneous coronary revascularization, PMID = PubMed ID, Revasc = revascularization, RR = risk ratio, y = years. See page 16 for study acronyms

* Nonrandomized comparative study

† 97.5% confidence interval

‡ P value refers to comparison of subgroups across all three study arms. (ICD, amiodarone, and placebo).

§ Only the LVEF <30% subgroup analysis was reported. The alternative group given here is from the total analysis, regardless of LVEF.

Appendix Table 6 ICD vs. No ICD: Results for 30 d mortality

Study Author, Year PMID | Outcome name | Timepoint | Outcome description | Intervention (Control) | Events Intervention (Control) | N analyzed Intervention (Control) | Metric | Results (95% CI) | p-value between arms
CABG-Patch Bigger, 1997 9371853 | Death, all-cause at 30 d | 30 d | Death in the first 30 days | ICD (No ICD) | 24 (20) | 446 (454) | nd | nd | 0.60
MADIT Moss, 1996 8960472 | Death, all-cause at 30 d | 30 d | NR | ICD (No ICD) | 0 (0) | 95 (101) | nd | nd | nd

CI=confidence interval, d= day, ICD=implantable cardiac defibrillator, nd=not documented

Appendix Table 7 ICD vs. No ICD: Results for sudden cardiac (arrhythmic) death

Study Author, Year PMID | Outcome name | Timepoint | Outcome description | Intervention (Control) | Events Intervention (Control) | N analyzed Intervention (Control) | Metric | Results (95% CI) | p-value between arms
5 y
MADIT Moss, 1996 8960472 | Death, cardiac arrhythmia | 5 y | Classification of Hinkle and Thaler 13 was used to evaluate the suspected mechanism of death from cardiac causes (arrhythmic or nonarrhythmic). “Abrupt loss of consciousness and disappearance of pulse without prior collapse of the circulation” (w/ or w/o CHF; witnessed or not) | ICD (No ICD) | 3 (13) | 95 (101) | nd | nd | nd
3 y
Chan, 2009 20031808 | Death, cardiac arrhythmia | 3 y | Death arrhythmic, Modified Hinkle and Thaler: unwitnessed deaths (if stable when last observed within 24 hours before death), witnessed instantaneous deaths, and sequelae of cardiac arrest. | ICD (No ICD) | 46 (105) | 494 (471) | Adjusted HR | 0.65 (0.40-1.03) | 0.07
DINAMIT Hohnloser, 2004 15590950 | Death, cardiac arrhythmia | 3 y | Death due to cardiac arrhythmia from witnesses, family, death certificate, hospital records, autopsy. Not ICD telemetry | ICD (No ICD) | 12 (29) | 332 (342) | HR | 0.42 (0.22-0.83) | 0.009
IRIS Steinbeck, 2009 19812399 | Death, cardiac arrhythmia | 3 y | A death, either in the hospital or out of the hospital, was assumed to be a sudden cardiac death if a cardiac death occurred within minutes after the onset of acute symptoms, resulted from a documented cardiac arrhythmia, or was not witnessed and occurred unexpectedly and without recognizable causes (e.g., during sleep). Furthermore, a death was classified as a sudden cardiac death regardless of the underlying condition. | ICD (No ICD) | 27 (60) | 445 (453) | HR | 0.55 (0.31-1.00) | 0.049
2 y
AMIOVIRT Strickberger, 2003 12767651 | Death, cardiac arrhythmia | 2 y | Sudden cardiac death (actual death); Cardiac death, SCD, duration of follow up 2.2 y | ICD (Amiodarone) | 1 (2) | 51 (52) | nd | nd | 0.7
DEFINITE Kadish, 2004 15152060 | Death, cardiac arrhythmia | 2 y | Sudden death from arrhythmia | ICD (No ICD) | 3 (14) | 229 (229) | HR | 0.20 (0. 60-0.71) | 0.001
Fonarow, 2000 10760339 | Death, cardiac arrhythmia | 2 y | Witnessed cardiac arrest or death within at least 1 hour after onset of acute symptoms or unexpected, unwitnessed death in a patient known to have been well within the previous 24 hours | ICD (Control) | 0 (18) | 25 (122) | nd | nd | 0.05
Fonarow, 2000 10760339 | Death, cardiac arrhythmia | 2 y | Actuarial survival | ICD (Control) | 100% (78.3%) | 25 (122) | nd | nd | 0.05
1 y
CAT Bansch, 2002 11914254 | Death, all-cause longest follow-up | 1 y | Sudden cardiac death | ICD (No ICD) | 0 (0) | 50 (54) | nd | nd | nd

CHF=chronic heart failure, CI=confidence interval, CRT-D=cardiac resynchronization therapy defibrillator, HR=hazards ratio, ICD=implantable cardiac defibrillator, mo=month, nd=not documented, y=year

For study names, see Appendix Table 1.

Appendix Table 8 Risk of bias

Study Author, Year PMID | Overall | Random'n | Alloc Conc | Blinding | Attr'n | ITT | Base Similar | Coint'n | Other Factors | Crossover to ICD | Crossover to no ICD
ICD vs. no ICD
AMIOVIRT Strickberger, 2003 12767651 | Good | Low | Unclear | Low | Low | Low | Low | Low | Yes, highly underpowered | 8/52 (15%) | 3/51 (6%) heart transplants; 11/51 (22%) also started amiodarone
CABG-Patch Bigger, 1997 9371853 | Fair^7^ | Low | Low | High | Low | Low | Low | Low | Yes, differential crossover | 18/454 (4%) | 52/446 (12%)
CAT Bansch, 2002 11914254 | Good | Low | Low | Unclear | Low | Low | Low | Low | Yes, highly underpowered | nd | nd
Chan, 2009 20031808 | -- | -- | -- | -- | -- | -- | -- | -- | Yes, observational study | 77/456 (17%) | nd
COMPANION Bristow, 2004 15152059 | Fair | Low (implied) | Unclear | High | High | Low | Low | Low | Yes, differential attrition and crossover (patients censored when crossed over) | 26% | 6.5%
DEFINITE Kadish, 2004 15152060 | Fair | Low | Unclear | Low | Low | Low | Low | Low | Yes, differential crossover | 23/229 (10%) | 4/229 (2%)
DINAMIT Hohnloser, 2004 15590950 | Good | Low | Low | Low | Low | Low | Low | Low | No | nd | 22/332 (7%)
Fonarow, 2000 10760339 | -- | -- | -- | -- | -- | -- | -- | -- | Yes, observational study | 0/122 (0%) | 1/25 (4%)
IRIS Steinbeck, 2009 19812399 | Good | Low (implied) | Unclear | Low | Low | Low | Low | Low | No | 39/463 (8%) | 45/445 (10%)
MADIT Moss, 1996 8960472 | Good | Low | Unclear | Unclear | Low (14%) | Low | Low | Low | No | 11/101 (11%) | 7/95 (7%)
MADIT II Moss, 2002 11907286 | Good^8^ | Low (implied) | Unclear | High | Low | Low | Low | Low | No | 22/490 (4%) | 44/742 (6%)
Mezu, 2011 21640321 | -- | -- | -- | -- | -- | -- | -- | -- | Yes, observational study | nd | nd
OPTIMIZE-HF and GWTG-HF Hernandez, 2010 20009044 | -- | -- | -- | -- | -- | -- | -- | -- | Yes, observational study | nd | nd
SCD-HeFT Bardy, 2005 15659722 | Fair | Low (implied) | Unclear | Unclear | Low | Low | Low | High | Yes, differential crossover; differential use of beta blockers^9^ | 118/1676 (11%) | 50/829 (6%)
ICD vs. CRT-D
Diab, 2011 21700757 | Good | Low | Low | Low | Low | Low | Low | Low | Yes, powered for echo outcomes | nd | nd
MADIT-CRT Moss, 2009 19723701 | Good | Low (implied) | Unclear | Low | Low | Low | Low | Low | No | ICD->CRT 91/731 (12%); CRT->ICD 82/1089 (8%) | 30/1820 (2%)
MENDMI Chung, 2010 20852059 | Fair | Low (implied) | Unclear | Unclear | High | Low | Low | Low | Yes, powered for LVEDV | nd | nd
RAFT Tang, 2010 21073365 | Good | Low | Unclear | Low | Low | Low | Low | Low | Yes, powered for the primary outcome, a composite of death or hospitalization for heart failure | nd | nd

7 Poor outcome other than all-cause mortality

Random'n: Randomization—What is the risk of selection bias (biased allocation to interventions) due to inadequate generation of a randomized sequence?

Alloc Conc: Allocation Concealment—What is the risk of selection bias (biased allocation to interventions) due to inadequate concealment of allocations before assignment?

Blinding: Outcome Assessor Blinding—For each main outcome or class of outcomes, what was the risk of detection bias due to knowledge of the allocated interventions by outcome assessment (lack of outcome assessor blinding)?

Attr'n: Attrition—For each main outcome or class of outcomes, what is the risk of attrition bias due to amount, nature, or handling of incomplete outcome data?

ITT: Intention-to-Treat—Were all randomized participants analyzed in the group to which they were allocated?

Base Similar: Groups Similarity—Were the groups similar at baseline regarding the most important prognostic indicators?

Coint'n: Cointerventions—Were co-interventions avoided or similar?

Other Factors: Are there other risks of bias? If yes, describe them in Notes?

Crossovers: Numbers of crossovers from one intervention to the other.

8 Fair outcomes other than all-cause mortality

9 Except in the use of beta-blockers at the time of the last follow-up visit (P<0.001). Amiodarone 72%; Placebo 79%; ICD 82%

nd=not documented

For study names, see Appendix Table 1.

Appendix Table 9 Quality of life in comparative studies of ICDs for primary prevention of SCD

Study Author, Year PMID | N | Study Duration | Intervention | QoL Instrument | Favors^*^ | Net Difference^†^ | 95% CI^†^ | Test | Range | P Value
Study Author, Year PMID | N | Study Duration | Intervention | QoL Instrument | Favors^*^ | Net Difference^†^ | 95% CI^†^ | “Worst” | “Best” | P Value
MADIT II Noyes, 2007 17446823 | 1,232 | 3 y | ICD vs. conventional treatment | Health Utility Index 3 | 0 | -0.068 | - | -0.371 | 1.0 | NS
AMIOVIRT Strickberger, 2003 12767651 | 103 | 1 y | ICD vs. Amiodarone | Quality of Well-being Schedule | 0 | +7 | -0.1, +14 | 0 | 110 | NS
AMIOVIRT Strickberger, 2003 12767651 | 103 | 1 y | ICD vs. Amiodarone | State Trait Anxiety Inventory | 0 | -2 | -10, +6 | 40 | 160 | NS
CABG Patch Namerow, 1999 10527011 | 490 | 6 mo | ICD vs. control | SF-36: Physical Limitations | 0 | -7.5 | - | 0 | 100 | NS
CABG Patch Namerow, 1999 10527011 | 490 | 6 mo | ICD vs. control | Role - Physical | 0 | -3.5 | - | 0 | 100 | NS
CABG Patch Namerow, 1999 10527011 | 490 | 6 mo | ICD vs. control | Bodily Pain | 0 | -1.4 | - | 0 | 100 | NS
CABG Patch Namerow, 1999 10527011 | 490 | 6 mo | ICD vs. control | General Health | 0 | -3.5 | - | 0 | 100 | NS
CABG Patch Namerow, 1999 10527011 | 490 | 6 mo | ICD vs. control | Social Limitations | 0 | -0.3 | - | 0 | 100 | NS
CABG Patch Namerow, 1999 10527011 | 490 | 6 mo | ICD vs. control | Role - Emotional | No ICD | -11.9 | - | 0 | 100 | 0.003
CABG Patch Namerow, 1999 10527011 | 490 | 6 mo | ICD vs. control | Mental Health | No ICD | -4.7 | - | 0 | 100 | 0.004
CABG Patch Namerow, 1999 10527011 | 490 | 6 mo | ICD vs. control | Perception of Health Transition | No ICD | +0.3 | - | 5 | 1 | 0.030

CABG Patch= Coronary Artery Bypass Graft Patch; CI=confidence interval; HRQOL=health-related quality of life; ICD=implantable cardioverter-defibrillator; MADIT II=Multicenter Automatic Defibrillator Implantation Trial II; mo=month; NS=not statistically significant; PMID=PubMed ID; QOL=quality of life; y=year

* Notes arm with statistically significantly better change in QOL

† (ΔQOL ICD arm – ΔQOL Treatment arm), data calculated

[underlined: Health Utility Index] (HUI3) “is a questionnaire that assesses HRQOL across 8 attributes: vision, hearing, speech, ambulation, dexterity, emotion, cognition, and pain and discomfort and can take values between -0.371 and 1, with -0.371 being the worst possible health state, 0 being death, and 1 being the best possible health state.” PMID 17446823

[underlined: Perception of Health Transition] Patients assess their current health status relative to 1 year before. Higher scores represent the perception that health status has gotten worse. PMID 10527011

[underlined: Quality of Well-being Schedule] “A higher level of general well-being is associated with a greater value.” The score range is 0 to 110. PMID 12767651

[underlined: SF-36] “The Medical Outcomes Study 36-Item Short-Form health survey is a widely used health status questionnaire comprised of 36 items… The SF-36 health survey taps 8 health concepts: physical functioning, role limitations due to physical problems, bodily pain, general health perceptions, vitality, social functioning, role limitations due to emotional problems, mental health, health transition (perceived change in health).” PMID 10747763

[underlined: State Trait Anxiety Inventory] (STAI) “The score range is 40 to 160. A greater value is associated with a lower level of anxiety.” [PMID 12767651] The scale and direction of this scale is different from other reports using STAI.

Appendix Table 10 Relationship between shocks and quality of life in patients with ICDs for primary prevention of SCD

Study Author, Year PMID | N | Study Duration | Comparison | % With Any Shock | QoL Instrument | | Favors^*^ | Net Difference^†^ | Test | Range | P Value
Study Author, Year PMID | N | Study Duration | Comparison | % With Any Shock | QoL Instrument | | Favors^*^ | Net Difference^†^ | | | P Value
Study Author, Year PMID | N | Study Duration | Comparison | % With Any Shock | QoL Instrument | | Favors^*^ | Net Difference^†^ | “Worst” | “Best” | P Value
MADIT-II Noyes, 2009 19929037 | 983 | 3 y | Shock (with ICD) vs. no shock (with or without ICD) | nd | Health Utility Index 3 | | No shocks | -0.044 adjusted ‡ | -0.371 | 1.0 | 0.037
CABG Patch Namerow, 1999 10527011 | 262 | 6 mo | Shock vs. no shock (all with ICD) | 38.5% | SF-36: | Physical Limitations | 0 | -8.0 | 0 | 100 | NS
CABG Patch Namerow, 1999 10527011 | 262 | 6 mo | Shock vs. no shock (all with ICD) | 38.5% | | Physical Functioning | 0 | -8.3 | 0 | 100 | NS
CABG Patch Namerow, 1999 10527011 | 262 | 6 mo | Shock vs. no shock (all with ICD) | 38.5% | | Bodily Pain | 0 | -1.0 | 0 | 100 | NS
CABG Patch Namerow, 1999 10527011 | 262 | 6 mo | Shock vs. no shock (all with ICD) | 38.5% | | General Health | 0 | -4.5 | 0 | 100 | NS
CABG Patch Namerow, 1999 10527011 | 262 | 6 mo | Shock vs. no shock (all with ICD) | 38.5% | | Social Functioning | 0 | -2.8 | 0 | 100 | NS
CABG Patch Namerow, 1999 10527011 | 262 | 6 mo | Shock vs. no shock (all with ICD) | 38.5% | | Role Emotional | 0 | -10.4 | 0 | 100 | NS
CABG Patch Namerow, 1999 10527011 | 262 | 6 mo | Shock vs. no shock (all with ICD) | 38.5% | | Mental Health | 0 | -3.0 | 0 | 100 | NS
CABG Patch Namerow, 1999 10527011 | 262 | 6 mo | Shock vs. no shock (all with ICD) | 38.5% | Perception of Health Transition | | 0 | +0.2 | 5 | 1 | NS

CABG Patch= Coronary Artery Bypass Graft Patch; ICD=implantable cardioverter-defibrillator; MADIT II=Multicenter Automatic Defibrillator Implantation Trial II; mo=month; NS=not statistically significant; PMID=PubMed ID; QOL: quality of life; y: year.

* Notes whether shocks or no shocks have a statistically significant association with better QOL.

† (ΔQOL ICD arm – ΔQOL Treatment arm)

‡ Effect size of ICD shock since last HRQOL assessment (at 3, 12, 24 and 36 mo after randomization) adjusted for clinical events and randomization to ICD vs. no ICD arm. On Health Utility Index 3 scale, 1 represents perfect health, 0 represents death, and negative values implies HRQOL worse than death.

Appendix Table 11 Quality of reporting for adverse events

Study, Author, Year, PubMed ID | Q1 | Q1a | Q2 | Q3 | Q4 | Q5 | Q6^*^ | Q7^†^ | Q8
Comparative studies
ADRIA, Sticherling, 2011, 21156772 | Yes | Yes | Yes | Yes | nd | Yes | Yes | Yes | Yes^‡^
ALTITUDE, Saxon, 2010, 21098452 | Yes | Yes | Yes | Yes | nd | Yes | Yes | Yes | No
MADIT-CRT Moss, 2009, 19723701 Moss, 2005, 16274414 (protocol) | No | -- | -- | Yes | nd | Yes | Yes | Yes | No
MADIT-RIT Moss, 2012 , 23131066 | Yes | Yes | Yes | Yes | nd | Yes | Yes | Yes | Yes
MENDMI, Chung, 2010, 20852059 | Yes | No | Yes | Yes | nd | Yes | Yes | Yes | Yes^‡^
Morrison, 2011, 21737019 | Yes | Yes | Yes | Yes | nd | Yes | Yes | Yes | Yes
RAFT, Tang, 2010, 21073395 Parkash, 2012, 23159551 Tang, 2009, 19102034 (protocol) | No | -- | -- | Yes | nd | Yes | Yes | Yes | Yes^‡^
RIGHT, Gold, 2012, 21978966 | Yes | Yes | Yes | Yes | nd | Yes | Yes | Yes | Yes
ICD arms from RCTs
MADIT II, Moss, 2002, 11907286 § | No | -- | -- | nd | nd | No | Yes | Yes | --
SCD-HeFT, Bardy, 2005, 15659722 Freudenberger, 2007, 17485579 | No | -- | -- | Yes | nd | Yes | Yes | Yes | --
Cohort studies
NCDR ICD Database, 11 papers ║ | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | --
EPD-Vision 2009-2012, 5 papers ¶ | Yes | Yes | Yes | Yes | nd | Yes | Yes | Yes | --
Birnie, 2012, 22311781 | Yes | Yes | Yes | nd | nd | No | Yes | Yes | --
Bode, 2012, 22753865 | Yes | Yes | Yes | nd | nd | Yes | Yes | Yes | --
Brullmann 2012, 22154315 | No | -- | -- | Yes^**^ | nd | Yes | Yes | Yes | --
Brumberg, 2012, 22519559 | Yes | Yes | Yes | nd | nd | No | Yes | Yes | --
Charytan, 2011, 21664735 | Yes | Yes | Yes | nd | nd | No | Yes | Yes | --
Cheung, 2012, 22923271 | Yes | Yes | Yes | Yes | nd | Yes | Yes | Yes | --
Desai, 2010, 20403488 | Yes | Yes | Yes | Yes | nd | Yes | Yes | Yes | --
Ditchl, 2011, 21678454 | Yes | Yes | Yes | Yes | nd | Yes | Yes | Yes | --
Gradeus, 2003, 12914630 | Yes | No | Yes | Yes | nd | Yes | Yes | Yes | --
Hauser, 2012, 22396584 | Yes | Yes | Yes | Yes | nd | Yes | Yes | Yes | --
Landolina, 2011, 21576653 | Yes | Yes | Yes | Yes | nd | Yes | Yes | Yes | --
Larsen, 2010, 20186244 | Yes | Yes | Yes | nd | nd | No | Yes | Yes | --
Lee, 2010 20170816; McFadden 2012, 22312139 | Yes | Yes | Yes | Yes | nd | Yes | Yes | Yes | --
Lyman, 2011, 21795298 | Yes | Yes | Yes | nd | nd | No | Yes | Yes | --
Kleeman, 2012, 22313314 | Yes | Yes | Yes | Yes | nd | Yes | Yes | Yes | --
Porterfield, 2010, 19925609 | Yes | Yes | Yes | nd | nd | Yes | Yes | Yes | --
Remmelts, 2009, 19325900 | Yes | Yes | Yes | nd | nd | No | Yes | Yes | --
Sandesara, 2011, 21086086 | Yes | Yes | Yes | Yes | nd | Yes | Yes | Yes | --
Schaer, 2011, 21712284 | Yes | No | Yes | Yes | Yes | Yes | Yes | Yes | --
Sengupta, 2012, 22314669 | No | -- | -- | nd | nd | No | Yes | Yes | --
Sweeney, 2012, 22387371 | Yes | Yes | Yes | Yes | nd | Yes | No^††^ | Yes | --
Sweeney, 2010, 21085109 | Yes | No | Yes | Yes | nd | No | Yes | Yes | --
Sweeney, 2005, 15927965 | Yes | Yes | Yes | Yes | nd | Yes | Yes | Yes | --
Tsai, 2010, 19262366 | No | -- | -- | nd | nd | No | Yes | Yes | --
Tzogias, 2012, 22314669 | Yes | Yes | Yes | nd | nd | No | Yes | Yes | --
Varma, 2010, 20716717 | Yes | Yes | Yes | Yes | nd | Yes | Yes | Yes | --
Total Yes/Total | 31/38 | 27/31 | 27/27 | 26/38 | 2/38 | 27/38 | 37/38 | 38/38 | 6/8

[underlined: Modified McHarms]

Q1 Were any harms prespecified (a priori) in Methods section?
Q1a If yes, were any of them prespecified with a priori standardized or precise definitions?
Q2 Were all prespecified harms reported?
Q3 Was the mode of harms collection ACTIVE (sought to collect information on AEs)?
Q4 Was the mode of harms collection PASSIVE? (Participants are not specifically asked about or tested for the occurrence of adverse events. Rather, adverse events are identified based on patient reports made on their own initiative.)
Q5 Did the study specify the TIMING and/or FREQUENCY of collection of harms?
Q6 Is the number of participants who experience harms provided for each arm?
Q7 Is the number at risk for harms (denominator) provided for each arm?
Q8 For studies comparing adverse events across two or more arms: Is there a STATISTICAL analysis of relative harms between groups?

EPD-Vision=Cardiology Information System, Leiden University Medical Center; ICD=implantable cardioverter-defibrillator; NCDR: National Cardiovascular Data Registry; nd=not documented; RCT=randomized, controlled trial. For study name abbreviations, see Appendix Tables 1 and 16.

* Studies had to report number of patients affected.

† Studies had to report number of patients at risk.

‡ Not all outcomes

§ Additional information from protocol paper: Moss, et al. Annals of Noninvasive Electrocardiology. 1999;4(1):83-91. .

║ PMIDs: 22095828, 21878667, 21537001, 19383957, 21050975, 21867834, 20863954, 21487093, 19879533, 21883101 and 19221223

¶ PMIDs: 21208947, 19808497, 22056722, 22094073 and 21272746

** Active collection for inappropriate shocks. No data for other outcomes.

†† Number of patients affected not documented. Study used for subgroup table only.

Appendix Table 12 Early (in-hospital) adverse events from the NCDR ICD database - Study characteristics

Author, Year PMID | N | Primary Prevention | Dates | # Sites^*^ | Exclusion Criteria (Prior ICD excluded, unless noted)
Freeman, 2012 22095828 | 356,515 | 82% | 04/06-03/10 | 1473 | Epicardial lead placement Missing physician data
Haines, 2011 21537001 | 268,701 | 78% | 01/06-06/08 | 1300 | Pts requiring thoracotomy Includes patients with prior ICD
Cheng, 2010 21050975 | 226,764 | nd | 04/06-09/08 | nd
Freeman, 2010 20863954 | 224,233 | 81% | 01/06-12/08 | 1356 | Epicardial lead placement Hospitals not reporting all implants per quarter of data
Aggarwal, 2009 19879533 | 164,069 | 68%^†^ | 01/06-12/07 | 1241 | Missing ESRD status data
Peterson, 2009 19221223 | 161,470 | 72% | 01/06-12/07 | 1224
Tsai, 2011 21878667 | 150,264 | 100% | 01/06-12/08 | nd | Secondary prevention Hospitals only submitting data on Medicare patients
Curtis, 2009 19383957 | 111,293 | 83% | 01/06-06/07 | 1062 | Age <18 Epicardial lead placement Physician <10 procedures during study
Dewland, 2011 21867834 | 104,049 | 82% | 01/06-12/07 | nd | Biventricular ICD
Wei, 2011 21487093 | 53,198 | 77%^†^ | 01/06-12/08 | 1300 | No data for serum BNP May include prior ICD as this is not stated as exclusion
Tsai, 2011 21883101 Subgroup only | 44,805 | 100% | 01/06-12/08 | nd | Do not meet MADIT II criteria, which are MI >40 days, LVEF ≤ 30%, NYHA I, II or III

ESRD=end stage renal disease; ICD=implantable cardioverter–defibrillator; LVEF=left ventricular ejection fraction; MADIT II=Multicenter Automatic Defibrillator Implantation Trial II; MI=myocardial infarction; NCDR=National Cardiovascular Data Registry; nd=not documented; NYHA=New York Heart Association; PMID=PubMed ID

* Number of sites is limited to sites achieving NCDR Data Reporting Quality thresholds. It is unclear if and why this would be different in studies with same time period.

† Calculated

Appendix Table 13 Percentage of patients with early (in-hospital) adverse events in NCDR ICD database

| Author Year PMID N | Freeman 2012 22095828 356,515 | Haines 2011 21537001 268,701 | Cheng 2010 21050975 226,764 | Freeman 2010 20863954 224,233 | Aggarwal 2009 19879533 164,069 | Peterson 2009 19221223 161,470 | Tsai 2011 21878667 150,264 | Curtis 2009 19383957 111,293 | Dewland 2011 21867834 104,049 | Wei 2011 * 21487093 53,198
Outcomes | Range^*^
Any adverse event | 2.77–3.55 | 3.08 | 3.05 | -- | 3.19 | 3.6^†^ | 3.55 | 3.26 | 3.7 | 2.77^†^ | 4.59^†^
Any serious adverse event | 1.17–1.35 | 1.17 | -- | -- | 1.20 | 1.3^†^ | 1.35 | 1.2^†,‡^ | -- | -- | --
Any adverse event or death | 1.5–3.37 | -- | 3.2 | -- | -- | -- | -- | 3.37 | 1.5 | -- | 1.97^†^
Arteriovenous fistula | <0.1 | -- | <0.01 | -- | -- | 0.01^†^ | 0.01 | 0 | <0.1 | <0.01^†^ | 0.01^†^
Cardiac arrest | 0.26–0.34 | 0.29 | 0.30 | 0.32^†^ | 0.3 | 0.3^†^ | 0.34 | 0.26 | 0.3 | 0.28^†^ | 0.69^†^
Cardiac perforation | 0.06–0.1 | -- | 0.07 | 0.08^†^ | -- | 0.08^†^ | 0.08 | 0.07 | 0.1 | 0.06^†^ | 0.07^†^
Cardiac valve injury | <0.1 | -- | <0.01 | -- | -- | § | 0 | -- | <0.1 | <0.01^†^ | --
Conduction block | 0.03–0.1 | -- | 0.03 | -- | -- | 0.04^†^ | 0.04 | 0.04 | 0.1 | 0.03^†^ | 0.04^†^
Coronary venous dissection | 0.08–0.15 | 0.12 | 0.12 | -- | -- | 0.15^†^ | 0.15 | -- | 0.1 | 0.08^†^ | 0.19^†^
Drug reaction | 0.09–0.11 | -- | 0.09 | 0.09^†^ | -- | 0.1^†^ | 0.11 | -- | 0.1 | 0.10^†^ | 0.15^†^
Hematoma | 0.84–1.1 | 0.86 | 0.93 | 1.01^†^ | -- | 1.0^†^ | 1.06 | 0.94 | 1.1 | 0.84^†^ | 1.39^†^
Hemothorax | 0.07–0.1 | -- | 0.08 | 0.09^†^ | 0.9 | 0.1^†^ | 0.10 | 0.09 | 0.1 | 0.07^†^ | 0.12^†^
Infection related to device | <0.1 | -- | 0.03 | 0.02^†^ | -- | 0.03^†^ | 0.03 | -- | <0.1 | 0.03^*^ | 0.06^*^
Lead dislodgement | 0.73–1.2 | 1.02 | 0.93 | 1.2 | 1.0 | 1.1^†^ | 1.09 | -- | 1.0 | 0.73^†^ | 1.24^†^
Myocardial infarction | <0.1 | -- | 0.02 | -- | -- | 0.03^†^ | 0.03 | 0.03 | <0.1 | 0.03^†^ | 0.05^†^
Pericardial tamponade | 0.07–0.1 | -- | 0.07 | -- | -- | 0.1^†^ | 0.09 | 0.10 | 0.1 | 0.07^†^ | 0.08^†^
Peripheral embolism | <0.1 | -- | 0.03 | 0.03^†^ | -- | 0.03^†^ | 0.03 | -- | 0 | 0.03^†^ | 0.06^†^
Peripheral nerve injury | <0.1 | -- | <0.01 | -- | -- | § | 0 | -- | <0.1 | <0.01^†^ | 0.01^†^
Phlebitis, deep | <0.1 | -- | 0.02 | -- | -- | 0.03^†^ | 0.03 | -- | <0.1 | 0.02^†^ | 0.06^†^
Phlebitis, superficial | 0.04–0.1 | -- | 0.04 | 0.04^†^ | -- | 0.1^†^ | 0.05 | -- | 0.1 | 0.05^†^ | 0.07^†^
Pneumothorax | 0.42–0.51 | 0.44 | 0.42 | 0.48^†^ | 0.5 | 0.5^†^ | 0.51 | 0.45 | 0.5 | 0.46^†^ | 0.58^†^
Stroke/CVA | 0.05–0.1 | -- | 0.06 | -- | -- | 0.1^†^ | 0.07 | 0.05 | 0.1 | 0.06^†^ | 0.12^†^
Transient ischemic attack | <0.1 | -- | 0.02 | -- | -- | 0.02^†^ | 0.02 | 0.03 | <0.1 | 0.02^†^ | 0.04^†^

CVA=cerebrovascular accident; ICD=implantable cardioverter–defibrillator; NCDR=National Cardiovascular Data Registry; PMID=PubMed ID

* Data from Wei, 2011 PMID 21487093 are outliers and are not included. All patients in this study had B-type natriuretic peptide (BNP) measurement which may represent patients with heart failure. Also the study did not explicitly exclude patients with prior ICD.

† Calculated.

‡ From figure.

§ Likely error in original paper: rate for cardiac valve injury (3%) and peripheral nerve injury (8%) are inconsistent with other studies from NCDR ICD database.

Appendix Table 14 P values for comparisons of early (in-hospital) adverse events by patient subgroup in the NCDR ICD database

| Primary vs. Secondary Prevention | Dual- vs. Single-chamber ICD^*^ | CRT-D vs. Single-chamber ICD^*^ | Older age^†^ | Female^‡^ | Race / Ethnicity | DM | ESRD^§^ | Lower physician implant volume║ | Lower hospital implant volume^¶^
Any adverse event | -- | P<0.001 (I) P<0.05^**^ (B) nd (A,D,H) | P<0.05^**^ (B) nd (A,D,H) | P<0.001 (K) P<0.05^**^(B)^††^ nd (G) | P<0.001 (F) P<0.05^**^ (B) | -- | -- | P<0.0001 (E) | P<0.0001 (A) | P<0.0001 (D) nd (A)
Any serious adverse event | -- | nd (A,D) | nd (A,D) | nd (G) | P<0.001 (F) | -- | -- | P<0.0001 (E) | P<0.0001 (A) | P<0.0001 (D)
Any adverse event or death | NS (B) | P<0.001 (G) nd (H) | P<0.001 (G) nd (H) | P<0.0001 (B) P<0.05 (G)^‡‡^ | P<0.0001 (B) P<0.001(G) | P<0.01 (G)^§§^ Higher for Black | NS (B) | P<0.0001 (B) P<0.001 (G) | -- | --
Arteriovenous fistula | -- | NS (I) ¶¶ | -- | nd (G) ¶¶ | NS (F) ¶¶ | -- | -- | NS (E) | -- | --
Cardiac arrest | -- | P=0.01 (I) nd (A) | nd (A) | nd (G) | NS (F) | -- | -- | P<0.0001 (E) | -- | --
Cardiac perforation | -- | NS (I) | -- | nd (G) ¶¶ | P<0.001 (F) | -- | -- | NS (E) | -- | --
Cardiac valve injury | -- | NS (I) ¶¶ | -- | -- | NS (F) ¶¶ | -- | -- | *** | -- | --
Conduction block | -- | NS (I) ¶¶ | -- | nd (G) ¶¶ | P<0.001 (F) | -- | -- | NS (E) | -- | --
Coronary venous dissection | -- | P<0.001 (I) ¶¶ nd (A) | nd (A) | -- | P<0.001 (F) | -- | -- | P=0.05 (E) § Lower in ESRD | -- | --
Drug reaction | -- | NS (I) | -- | -- | P=0.015 (F) | -- | -- | P<0.0001 (E) | -- | --
Hemothorax | -- | NS (I) | -- | nd (G) | P<0.001 (F) | -- | -- | P=0.01 (E) | -- | --
Hematoma | -- | P<0.001 (I) nd (A) | nd (A) | nd (G) | NS (F) | -- | -- | P<0.0001 (E) | -- | --
Infection related to device | -- | NS (I) | -- | -- | NS (F) | -- | -- | NS (E) | -- | --
Lead dislodgement | -- | P<0.001 (I) P<0.05^**^ (C) nd (A) | P<0.05(C) ¶¶ nd (A) | NS (C) | P=0.002 (F) P<0.001 (C) | P=0.005 (C) Higher for White^†††^ | NS (C) | NS (E) | -- | --
Myocardial infarction | -- | P=0.05 (I) ¶¶ | -- | nd (G) ¶¶ | NS (F) | -- | -- | NS (E) | -- | --
Pericardial tamponade | -- | P=0.01 (I) | -- | nd (G) | P<0.001 (F) | -- | -- | NS (E) | -- | --
Peripheral nerve injury | -- | NS (I) ¶¶ | -- | -- | NS (F) ¶¶ | -- | -- | *** | -- | --
Peripheral embolism | -- | NS (I) ¶¶ | -- | -- | P=0.014 (F) | -- | -- | NS (E) | -- | --
Phlebitis - deep | -- | NS (I) ¶¶ | -- | -- | P=0.008 (F) | -- | -- | NS (E) | -- | --
Phlebitis - superficial | -- | P=0.009(I) | -- | -- | NS (F) | -- | -- | NS (E) | -- | --
Pneumothorax | -- | P<0.001 (I) nd (A) | nd (A) | nd (G) | P<0.001 (F) | -- | -- | NS (E) | -- | --
Stroke/CVA | -- | NS (I) | -- | nd (G) ¶¶ | NS (F) | -- | -- | NS (E) | -- | --
Transient ischemic attack | -- | NS (I) ¶¶ | -- | nd (G) ¶¶ | NS (F) ¶¶ | -- | -- | NS (E) | -- | --
Number of papers (reporting statistics) | 1 (1) | 7 (4) | 5 (2) | 4 (3) | 4 (4) | 2 (2) | 2 (2) | 4 (4) | 1 (1) | 2 (1)

A-J in parentheses indicate the specific studies. See Study Key, below.

P values <0.05 indicate statistically higher rates of AE in subgroup in column header, unless otherwise noted. NS indicates no statistical difference in AE between subgroups. “nd” indicates paper reported rates of AE by subgroup but did not report statistical comparison between groups.

AE=adverse event; CRT-D=cardiac resynchronization therapy-defibrillator; CVA=cerebrovascular accident; DM=diabetes mellitus; ESRD=end-stage renal disease; ICD=implantable cardioverter-defibrillator; NCDR=National Cardiovascular Data Registry;

* More leads resulted in higher rates of adverse events unless difference between groups NS.

† Adverse events were higher in older patients unless difference between groups NS. Age cutoffs varied between papers.

‡ Female sex resulted in higher rates of adverse events, unless difference between groups NS.

§ Rate of adverse events are higher in patients with ESRD unless difference between groups NS, with the following exception: rates of coronary venous dissection are 0.06% and 0.15%, for ESRD and non-ESRD groups, respectively (E).

║ Rates of adverse events decrease with higher physician implant volume, p=p trend.

¶ Rates of adverse events decrease with higher hospital implant volume, p=p trend.

** Paper reports odds or hazards ratio with confidence interval that does not cross 1.0. No p-value reported.

†† Rates of any adverse event increased statistically across the age groups ≤65, 65-75 and ≥75 (K) and with age >70 (B).

‡‡ Rates of any adverse event or death were statistically for age ≥75 (G) and with age >70 (B).

§§ Rates of any adverse event or death are higher in black subgroup, reference group not documented (G).

¶¶ Less than 10 events in at least one subgroup.

*** Paper reports NS between groups. However rate data is inconsistent in order of magnitude within paper and with other papers.

††† Rates of lead dislodgement differed across White, Black, Hispanic and Other subgroups with Whites having more events (C).

Study Key (author, year, PubMed ID)
A | Freeman, 2012 | 22095828
B | Haines, 2011 | 21537001
C | Cheng, 2010 | 21050975
D | Freeman, 2010 | 20863954
E | Aggarwal, 2009 | 19879533
F | Peterson, 2009 | 19221223
G | Tsai, 2011 | 21878667
H | Curtis, 2009 | 19383957
I | Dewland, 2011 | 21867834
J | Wei, 2011 | 21487093
K | Tsai, 2011 | 21883101

Appendix Table 15 Study characteristics of comparative studies of ICDs with adverse event data

Study Author, Year PMID | Country | N | Primary Prevention | Study Duration | No. Sites | Study Design | Inclusion/Exclusion Criteria | Age (Mean) | Male (%)
ICD vs. CRT-D
ALTITUDE Saxon, 2010 21098452 | US | 185,778 | nd | 2006-05/09^*^ | 2096 | Prospective cohort | [underlined: Inclusion]: All patients receiving ICD or CRT-D with Boston Scientific remote monitoring device | 67 | 74%
MADIT-CRT Moss , 2009, 19723701 | US | 1,820 | 100% | 12/04-04/08 | 110 | RCT | [underlined: Inclusion]: Age ≥21, ischemic cardiomyopathy (NYHA class I or II) or nonischemic cardiomyopathy (NYHA class II only), sinus rhythm, ejection fraction ≤30% and prolonged intraventricular conduction with a QRS duration ≥130 msec [underlined: Exclusion]: An existing indication for CRT, implanted pacemaker, ICD or CRT, NYHA class III or IV sympotoms, previous CABG, percutaneous coronary intervention, or MI within 3 mo; atrial fibrillation within 1 mo | 65 | 75%
RAFT Tang, 2010 21073365 Parkash, 2012 23159551 | Canada, Europe, Turkey, Australia | 1798 | 86% | 01/03-08/10 | 34 | RCT | [underlined: Inclusion]: Primary or secondary prevention, NHYA class II or III symptoms of heart failure despite receiving optimal medical therapy, LVEF ≤30%, ischemic or nonischemic causes, an intrinsic QRS duration ≥120 msec or paced QRS duration ≥200 msec, sinus rhythm or permanent atrial fibrillation or flutter with a controlled ventricular rate or planned atrioventricular-junction ablation after device implantation. [underlined: Exclusion]: Major coexisting illness or a recent cardiovascular event. | 66 | 83%
MENDMI Chung, 2010 20852059 | US | 80 | 100% | 04/05-03/08 | nd | RCT | [underlined: Inclusion]: Recent MI, QRS duration <120 msec, LVEF ≤35%, abnormal wall motion in at least 5 of 16 possible segments measured 2 to 14 days after presentation [underlined: Exclusion]: Permanent or persistent atrial tachyarrhythmia, cardiogenic shock, 2° or 3° heart block, marked renal dysfunction, CABG within 30 days, NYHA class IV, previous ICD or pacemaker or CRT device. | 57 | 75%
Single-vs. Dual- Chamber
ADRIA Sticherling, 2011 21156772 | Germany & Switzerland | 249 | nd | nd | 10 | RCT | [underlined: Inclusion]: age≥18, indication for ICD; [underlined: Exclusion]: Antibradycardia pacing, permanent atrial fibrillation | 63 | 87%

ADRIA= A+ versus DR Clinical Investigation of Arrhythmia Discrimination; ALTITUDE= the acronym is undefined CABG=Coronary Artery Bypass Graft; CRT-D=cardiac resynchronization therapy-defibrillator; ICD=implantable cardioverter–defibrillator; LVEF=left ventricular ejection fraction; MADIT-CRT=Multicenter Automatic Defibrillator Implantation Trial with Cardiac Resynchronization Therapy; MENDMI=Prevention of Myocardial Enlargement and Dilation Post Myocardial Infarction Study; MI=myocardial infarction; nd=not documented; No=number; NYHA=New York Heart Association; PMID=PubMed ID; RAFT= Resynchronization–Defibrillation for Ambulatory Heart Failure Trial; RCT=randomized, controlled trial; US=United States

* Month in 2006 in which data collection began was not documented.

Appendix Table 16 Adverse events from comparative studies of ICDs

Study Author, Year PMID | N | Primary Prevention | Intervention | Early Adverse Events | | | Late Adverse Events & Inappropriate shock
Study Author, Year PMID | N | Primary Prevention | Intervention | Followup | Outcome | % (P value^*^) | Followup | Outcome | % (P value^*^)
ICD vs. CRT-D
ALTITUDE Saxon, 2010 21098452 | 185,778 | nd | ICD vs. CRT-D | | -- | | 5 y | Inappropriate shocks | 16% vs. 17%
MADIT-CRT Moss, 2009 19723701 | 1,820 | 100% | ICD vs. CRT-D | In-hospital | Coronary venous dissection with pericardial effusion | 0% vs. 0.5% | 2.4 y | Total device-related AE | 5.2 vs. 4.5 †
MADIT-CRT Moss, 2009 19723701 | 1,820 | 100% | ICD vs. CRT-D | 30 days | Pneumothorax | 0.8% vs. 1.7% | 2.4 y | Total device-related AE | 5.2 vs. 4.5 †
MADIT-CRT Moss, 2009 19723701 | 1,820 | 100% | ICD vs. CRT-D | 30 days | Infection | 0.70% vs. 1.10% | 2.4 y | Total device-related AE | 5.2 vs. 4.5 †
MADIT-CRT Moss, 2009 19723701 | 1,820 | 100% | ICD vs. CRT-D | 30 days | Pocket hematoma req. evacuation | 2.5% vs. 3.3% | 2.4 y | Total device-related AE | 5.2 vs. 4.5 †
RAFT Tang, 2010 21073365 | 1798 | 86% | ICD vs. CRT-D | 30 days | Hemothorax or pneumothorax | 0.9% vs. 1.2% | | --
RAFT Tang, 2010 21073365 | 1798 | 86% | ICD vs. CRT-D | | Hematoma req. intervention | 1.2% vs.1.6%
RAFT Tang, 2010 21073365 | 1798 | 86% | ICD vs. CRT-D | | Pocket infection req. intervention | 1.8% vs. 2.4%
RAFT Tang, 2010 21073365 | 1798 | 86% | ICD vs. CRT-D | | Lead dislodgement req. intervention | 2.2% vs. 6.9%
RAFT Tang, 2010 21073365 | 1798 | 86% | ICD vs. CRT-D | | Pocket problems req. revision | 0.1% vs. 0.5%
RAFT Tang, 2010 21073365 | 1798 | 86% | ICD vs. CRT-D | | Coronary sinus dissection | 0% vs. 1.2%
MENDMI Chung, 2010 20852059 | 80 | 100% | ICD vs. CRT-D | -- | | | 1 y | Total AE | 42% vs. 52% (NS) ‡
Single- vs. Dual- Chamber
ADRIA Sticherling, 2011 21156772 | 249 | nd | Single-chamber vs. dual-chamber ICD § | In-hospital | Pneumothorax | 0.8% vs. 0.8% (NS)║ | 1 y | Inappropriate shocks | 5.6% vs. 5.6%^¶^
ADRIA Sticherling, 2011 21156772 | 249 | nd | Single-chamber vs. dual-chamber ICD § | In-hospital | Ventricular perforation | 0% vs. 0.8% (NS)║ | 1 y | Ventricular lead-related AE | 5.6% vs. 4.0% (NS)^**^

ADRIA= A+ versus DR Clinical Investigation of Arrhythmia Discrimination; AE=adverse events; ALTITUDE= the acronym is undefined; CRT-D=cardiac resynchronization therapy-defibrillator; ICD=implantable cardioverter–defibrillator; MADIT-CRT=Multicenter Automatic Defibrillator Implantation Trial with Cardiac Resynchronization Therapy; MENDMI=Prevention of Myocardial Enlargement and Dilation Post Myocardial Infarction Study; nd=not documented; PMID=PubMed ID; req=requiring; y=year

* P-value provided only if documented.

† Total device-related AE per 100 device-months

‡ Data calculated. Prespecified composite AE: Left ventricular lead dislodgement, postimplantation left ventricular lead repositioning, permanent failure to deliver biventricular pacing, ventricular tachyarrythmia, hospitalization due to cardiac causes and all-cause mortality.

§ ICD with a single-lead with an integrated atrial sensing rings mounted 15 to 18 cm from the tip of the ICD lead versus a dual lead (dual chamber) ICD

║ Data calculated

¶ Data calculated. 34 episodes in 7 patients vs. 12 episodes in 7 patients.

** Data calculated. Ventricular lead dislocation or high threshold. Follow-up time unclear (in-hospital or 12 months)

Appendix Table 17 Characteristics of studies of late adverse events and inappropriate shock

Author, Year PMID, Country | N | Primary Prevention | Study Duration | # Sites | Study Design | Inclusion/Exclusion Criteria | Age (mean) | Male (%)
ICD arms from RCTs^*^
SCD-HeFT Bardy, 2005 15659722, US | 829 | 100% | 09/97-10/03 | multiple | RCT | [underlined: Inclusion]: Age≥18, NYHA II –III, CHF due to ischemic or nonischemic causes, LVEF ≤ 35% | 60 median | 77^†^
MADIT II Moss, 2002 11907286 US & Europe | 742 | 100% | 07/97-11/01 | 76 | RCT | [underlined: Inclusion]: Age ≥21, >1 mo since MI and LVEF≤30 within 3 mo before entry, primary prevention [underlined: Exclusion]: Coronary revascularization within 3 mo, MI within 1 mo, NYHA class IV, adv anced cerebrovascular disease | 64 | 84
Other Studies
Birnie, 2012 22311781, Canada | 3,169 | 67% | 12/03-11/07 | 11 | Retrospective cohort | [underlined: Inclusion]: All pts receiving ICDs with Sprint Fidelis leads | 63 | 82^†^
Bode, 2012 22753865, Germany | 903 | nd | 01/93-12/09 (implant date) | 1 | Retrospective cohort | [underlined: Inclusion]: All pts receiving first transvenous ICD | 64 | 81
Borleffs, 2009 19808497, NL | 2,068^‡^ | 55% | 1992-02/08 | 1 | Prospective cohort | [underlined: Inclusion]: All pts receiving ICDs [underlined: Exclusion]: Receiving abdominal system or leads with coaxial construction or polyurethane coating | 61 | 80
Brumberg, 2012 22519559, US | 621 | nd | 05/04-12/07 (implant date) | 1 | Retrospective cohort | [underlined: Inclusion]: All pts receiving initial ICD, revision or upgrade with Fidelis lead | 66 | 75
Brullman, 2012 22154315 Austria, Switzerland | 936^§^ | 42%^†^ | 1987-2009 (implant dates) | 2 | Prospective cohort | [underlined: Inclusion]: Age ≥18 receiving first ICD for primary or secondary prevention or syncope^2^ | 63 median | 85
Charytan, 2011 21664735, US | 9,528 | <50% | 1994-2006 | nd | Registry | [underlined: Inclusion]: Age ≥21, all dialysis pts in USRDS implanted with ICD or CRT | 65 | 70
Cheung, 2012 22923271, US | 732 | 91% | 09/04-10/07 (implant date) | 1 | Retrospective cohort | [underlined: Inclusion]: All pts receiving Sprint Fidelis leads [underlined: Exclusion]: <90 days followup | 67 | 76^†^
De Bie, 2012 22056722, NL | 2,476 ‡ | 66% | 01/00-09/09 (implant date) | 1 | Prospective cohort | [underlined: Inclusion]: All pts receiving first ICD or CRT-D | 62 | 79
Desai, 2010 20403488, US | 549 | nd | nd | 1 | Retrospective cohort | [underlined: Inclusion]: Pts with heart failure receiving ICDs | 74 | 79^†^
Dichtl, 2011 21678454 Austria, Switzerland | 1,117^§^ | 40% | nd | 2 | Prospective cohort | nd | nd ║ | 81
RIGHT, Gold, 2012 21978966 US, Canada, Europe | 1962 | 85%^†^ | nd | 130 | RCT | [underlined: Inclusion]: Pts scheduled to receive ICD | 64 | 79^†^
Gradaus, 2003 12914630 Germany | 3,344 | 7.1% | 01/98-10/00 (implant date) | 62 | Retrospective cohort | [underlined: Inclusion]: All pts receiving ICDs | 61 | 80
Hauser, 2002 22396584, US | 2,710 | 75%^†^ | 11/01-11/09 | 3 | Retrospective cohort | [underlined: Inclusion]: All pts receiving Sprint Fidelis or Quattro Secure leads | 64^†^ | 77^†^
Kleeman, 2012 22313314, Germany | 1,411 | 32%^†^ | 1992-05/08 (implant date) | 1 | Prospective cohort | [underlined: Inclusion]: pts receiving ICDs for primary or secondary prevention | 66 | 79^†^
Landolina, 2011 21576653 Italy | 3,253 | 87% | 2004-2009 (implant date) | 117 | Prospective cohort | [underlined: Inclusion]: Consecutive pts receiving first single or dual-chamber ICD or CRT-D systems including pts with preexisting pacemakers. | 67 | 80
Larsen, 2010 20186244 New Zealand | 702 | 27%^†^ | 01/00-12/07 (implant date) | 2 | Retrospective cohort | [underlined: Inclusion]: All pts receiving first ICD | 53 | 77
Lee, 2010 20170816 Canada | 3,340^¶^ | 70% † | 02/07-05/09 | nd | Registry | [underlined: Inclusion]: De novo single- or dual-chamber ICD or CRT-D. [underlined: Exclusion]: <45 day followup | 64 | 79
Lyman, 2011 21795298, US | 38,992 | 100 | 1997-2006 | nd | Retrospective cohort | [underlined: Inclusion]: All primary ICD implantation admissions | 66 | 77
MacFadden, 2012 22312139, Canada | 5,213^¶^ | 72%^†^ | 02/07-07/10 | nd | Registry | [underlined: Inclusion]: De novo single- or dual-chamber ICD or CRT-D for primary or secondary prevention | 65 | 79
Morrison, 2011 21737019, US | 2,671 | 75% | 11/01-12/08 (implant date) | 3 | Prospective cohort | [underlined: Inclusion]: All pts receiving ICDs with Sprint Fidel is or Quattro Secure leads | 65^†^ | 77^†^
MADIT-RIT Moss, 2012 23131066 US & other^**^ | 1,500 | 100% | 09/09-07/12 | 98 | RCT | [underlined: Inclusion]: ≥21 yrs, ischemic or nonishchemic heart disease, sinus rhythm, standard indicatio n for ICD or CRT-D for primary prevention [underlined: Exclusion]: Prior ICD, Pacemaker or CRT; Atrial fibrillation; CABG, PCI or MI within 3 mo | 63^†^ | 71^†^
RAFT Parkash, 2012 23159551 | 1787 | 86% | 01/03-08/10 | 34 | RCT | [underlined: Inclusion]: Primary or secondary prevention, NH YA class II or III, LVEF ≤30% , ischemic or nonische mic causes, an intrinsic QRS duration ≥120 msec or paced QRS duration ≥200 msec. (See Appendix Table 14) [underlined: Exclusion]: Major coexisting illness or a recent cardiovascular event. | 66 | 83
Porterfield, 2010 19925609 US, Germany | 15,387 | nd | 06/01-11/07 | 28 | Retrospective cohort | [underlined: Inclusion]: Pts implanted with Riata lead model numbers from 1500 and 7000 series | 66 | 76
Remmelts, 2009 19325900, NL | 667 | nd | 01/96-10/06 (implant date) | 1 | Retrospective cohort | [underlined: Inclusion]: All pts receiving first ICD [underlined: Exclusion]: Pulse generator inserted in abdominal pocket or epicardial lead system | 58 | 77
INTRINSIC RV Sandesara, 2011 21086086, US | 1,528 | nd | nd | 108 | Post-hoc analysis of RCT | [underlined: Inclusion]: Indication for ICD and VITALITY AVT ICD implanted | 65 | 81^†^
ALTITUDE Saxon, 2010 21098452, US | 185,778 | nd | 2006-05/09 | 2096 | Prospective cohort | [underlined: Inclusion]: All pts receiving ICD or CRT-D with Boston Scientific remote monitoring device | 68^†^ | 75^†^
Schaer, 2011 21712284, NL | 536 | 100% | 1998-2008 | 2 | Retrospective cohort | [underlined: Inclusion]: All pts with CAD receiving ICD or CRT-D for primary prevention | 63 | 88
Sengupta, 2012 22314669 US | 1644 | 55% | 08/94-05/04 (implant date) | 1 | Retrospective cohort | [underlined: Inclusion]: All pts receiving first ICD [underlined: Exclusion]: Pts receiving investigational ICDs or ICDs with unclear advisory/non-advisory status | 63 | 78
Sweeney,2012 22387371, US Subgroups only | 1,464 | 100% | 08/05-04/11 | 134 | Prospective cohort | [underlined: Inclusion]:All pts receiving Medtronic ICD or CRT-D for primary prevention and LVEF ≤35% | 67 | 72
Sweeney, 2010 20185109, US | 2,135 | 67% | nd | nd | Post-hoc analysis of 4 Trials^††^ | [underlined: Inclusion]:All pts had Medtronic ICDs implanted less than 4 wks before enrollment | 66 | 80
PainFree RX II Sweeney, 2005 15927965, US Subgroups only | 582^‡‡^ | 43%^†^ | nd | nd | RCT | [underlined: Inclusion]: Pts receiving ICDs [underlined: Exclusion]: Pts unlikely to have substrate for stable monomorphic VT susceptible to pace termination | 68 | 79
Thijssen,2012 22094073, NL | 3,194^‡^ | 62% | 1996-04/11 | 1 | Prospective cohort | [underlined: Inclusion]: All pts receiving ICDs | 62 | 78
Tsai, 2010 19262366, US | 1,060 | nd | nd | 1 | Retrospective cohort | [underlined: Inclusion]: All pts receiving ICDs | 70 | 80
Tzogias, 2012 22314669, US | 971 | 85% | 09/04-07/07 (implant date) | 1 | Retrospective cohort | [underlined: Inclusion]: Al pts receiving Sprint Fidelis 6949 lead | 68 | 73
Van Rees, 2012 22352338, NL | 1,602^‡^ | 58% | 1996-02/11 | 1 | Prospective cohort | [underlined: Inclusion]: All pts receiving ICDs with transvenous leads [underlined: Exclusion]: Pts with Sprint Fidelis or Riata leads | 61 | 80
Van Rees, 2011 21272746, NL Subgroups only | 1,544^‡^ | 56% | 1996-2006 | 1 | Prospective cohort | [underlined: Inclusion]: All pts receiving ICDs | 61 | 79
Van Rees, 2012 21920909, NL Subgroups only | 1,395^‡^ | 100% | 01/96-01/09 | 1 | Prospective cohort | [underlined: Inclusion]: All pts receiving ICDs for primary prevention [underlined: Exclusion]: Congenital structural or monogenetic heart disease | 63 | 79
Van Welsenes 2011 21208947, NL | 2,134^‡^ | 61% | 1996-01/08 | 1 | Prospective cohort | [underlined: Inclusion]: All pts receiving ICD [underlined: Exclusion]: Congenital monogenetic cardiac disease, hypertrophic obstructive cardiomyopathy, long-QT syndrome, Brugada syndrome, and idiopathic VF, related to an increased risk of cardiac arrhythmia | 63 | 81^†^
TRUST Varma, 2010 20716717, US | 1,339 | 73%^†^ | 08/05-05/09 | 102 | RCT (remote monitoring vs. conventional) | [underlined: Inclusion]: Recipients of single- or dual-chamber ICDs for class I/II indications [underlined: Exclusion]: Pacemaker dependent | 64^†^ | 72^†^

ALTITUDE=acronym is undefined; CABG=coronary artery bypass grafting; CAD=coronary artery disease; CHF=congestive heart failure; CRT-D=cardiac resynchronization therapy-defibrillator; ICD=implantable cardioverter-defibrillator; INTRINSIC RV= Inhibition of Unnecessary RV Pacing with AV Search Hysteresis in ICDs; LVEF=left ventricular ejection fraction; MADIT II= Multicenter Automatic Defibrillator Implantation Trial II; MADIT-RIT= Multicenter automatic defibrillator implantation trial: reduce inappropriate therapy; MI=myocardial infarction; mo=month; nd=not documented; NL: Netherlands; NYHA=New York Heart Association; PCI=percutaneous coronary intervention; PMID:=PubMed ID; pts=patients; RCT=randomized, controlled trial; RIGHT=Rhythm ID Goes Head to Head Trial; RV=right ventricular; SCD-HeFT= Sudden Cardiac Death in Heart Failure Trial; TRUST= Lumos-T Safely Reduces Routine Office Device Follow Up; US=United States; USRDS=United States Renal Data System; VF=ventricular fibrillation; VT=ventricular tachycardia

* Includes ICD arm of trials from Key Question 1 with ≥500 patients with ICDs and nonICD control groups.

† calculated

‡ Likely patient overlap between Van Welsenes [21208947], Borleffs [19808497], de Bie [22056722], Thijssen [22094073], Van Rees [21920909], [22352338] and [21272746].

All data from Leiden University Medical Center Cardiology Information System (EPD-Vision).

§ Likely patient overlap between Brullman [22154315] and Ditchl [21678454].

║ 19.3% of patients age >70yr

¶ Patients in Lee [20170816] included in MacFadden [22312139].

** US, Canada, Israel, Japan and Europe

†† Four trials incorporating ATP to reduce shocks (PainFREE Rx, PainFREE Rx II, EMPIRIC, and PREPARE)

‡‡ All patients included in Sweeney, 2010, PMID 20185109

Appendix Table 18 Inappropriate shock (among studies with N ≥500)

Study Author, Year PMID | N | Mean followup | Device Type | Model | Patients with Inappropriate Shock (%) | Between Arm Comparison
Comparative studies
Morrison, 2011 21737019 | 1,030 | 34 mo | ICD or CRT-D | Medtronic Sprint Fidelis 6931, 6948, 6949 | 20% | P<0.001
Morrison, 2011 21737019 | 1,641 | 40 mo | ICD or CRT-D | Medtronic Quattro Secure 6947 | 14% | P<0.001
RIGHT Gold, 2012 21978966 | 985 | 18 mo | Single- or dual-chamber ICD | Guidant Vitality 2 with Rhythm ID | 18%^*^ | P<0.001^†^
RIGHT Gold, 2012 21978966 | 977 | 18 mo | Single- or dual-chamber ICD | Medtronic Maximo Marquis, Intrinsic, Virtuoso, or Entrust with Wavelet or Enhanced PR logic | 12%^*^ | P<0.001^†^
MADIT-RIT Moss, 2012 23131066 | 514 | 17 mo^*^ | Dual-chamber ICD or CRT-D | Conventional programming^‡^ | 6% | --
MADIT-RIT Moss, 2012 23131066 | 500 | | Dual-chamber ICD or CRT-D | High-rate therapy^‡^ | 3% | P=0.01 vs. conventional
MADIT-RIT Moss, 2012 23131066 | 486 | | Dual-chamber ICD or CRT-D | Delayed therapy^‡^ | 3% | P=0.03 vs. conventional
ICD arms from RCTs^§^
SCD-HeFT Bardy, 2005 15659722 | 829 | 46 mo median | Single-chamber ICD | Medtronic 7223 | 2.4% per year | --
Other Studies
ALTITUDE║ Saxon, 2010 21098452 | 185,778 | 60 mo | Single- or dual-chamber ICD or CRT-D | Boston Scientific remote-monitoring capable device | 16%^*^║ | --
Brullman, 2012 22154315 | 936^¶^ | 43 mo | Single- or dual-chamber ICD or CRT-D | nd | 21% | --
Van Welsenes, 2011 21208947 | 2,134 | 41 mo^*^ | Single- or dual-chamber ICD or CRT-D | Biotronik, Medtronic, Boston Scientific/ Guidant, St. Jude Medical/Ventritex | 14%^**^ | --
Desai, 2010 20403488 | 549 | 41 mo^††^ | ICD | nd | 13%^‡‡^ | --
Larsen, 2010 20186244 | 702 | 40 mo median | Single- or dual-chamber ICD or CRT-D | nd | 16% | --
Kleemann, 2012 22313314 | 1,411 | 36 mo^*^ | Single- or dual-chamber ICD or CRT-D | Biotronik, Medtronic, ELA Medical, Guidant, St. Jude Medical | 21%^§§^ | --
Dichtl, 2011 21678454 | 1,117^¶^ | 35 mo^*^ | Single- or dual-chamber ICD or CRT-D | nd | 21% | --
Schaer, 2011 21712284 | 536 | 30 mo | Single- or dual-chamber ICD or CRT-D | nd | 8.0% | --
MacFadden, 2012, 22312139 | 5,213 | 12 mo | Single- or dual-chamber ICD or CRT-D | nd | 3.0% | --
INTRINSIC RV Sandesara,2011 21086086 | 1,528 | 12 mo | Dual-chamber ICD | Guidant Vitality AVT | 6.3%^*^
Sweeney, 2010 20185109 | 2,135 | 12 mo^*^ | ICD | Medtronic | 8.6%*║║

ATP=antitachycardia pacing; bpm=beats per minute; CRT-D=cardiac resynchronization therapy-defibrillator; ICD=implantable cardioverter-defibrillator; mo=month; nd=not documented; PMID=PubMed ID; VF=ventricular fibrillation; VT=ventricular tachycardia. For study name acronyms see Appendix Table 16.

* calculated

† Single chamber ICDs Guidant vs. Medtronic p=0.003; dual chamber ICDs Guidant vs. Medtronic p=0.006

‡ Boston Scientific ICDs. [underlined: Conventional programming]: For 170 bpm (VT), 2.5 second delay, atrial discriminators on, ATP+shock. For 200 bpm (VF) 1.0 second delay, ATP+shock. [underlined: High rate therapy]: For 170 bpm (VT), monitor only. For 200 bpm (VF) 2.5 second delay, ATP+shock [underlined: Delayed therapy] For 170 bpm (VT-1), rhythm detection on, 60 second delay, ATP+shock For 200 bpm (VT) rhythm detection on, 12 second delay ATP+shock. For 250 bpm (VF) 2.5 second delay ATP+shock. In all devices, ATP was followed by shock therapy only if pacing did not terminate the tachycardia.

§ Includes ICD arm of trials from Key Question 1 with ≥500 patients with ICDs and nonICD control groups.

║ ALTITUDE study is also included in Appendix Table 15

¶ Likely patient overlap between Brullman [22154315] and Ditchl [21678454].

** Patients receiving inappropriate shocks experienced 2.9 +/- 4.5 shocks (mean.) Additional papers published from EPD-Vision Database with smaller numbers of patients and similar or shorter follow-up periods report rates of inappropriate shocks ranging from 10%-15% [PMID 21272746, 20185038, 20639206].

†† Unclear if follow-up begins at implantation.

‡‡ 187 inappropriate shocks in 71 patients

§§ 297 patients received 948 inappropriate shocks

║║ Four trials incorporating ATP to reduce shocks (PainFREE Rx, PainFREE Rx II, EMPIRIC, and PREPARE). Pain FREE RX II trial alone reports 9.1% of patients experiencing inappropriate shocks (PMID 15927965) with a followup of 11 months.

Appendix Table 19 Late adverse events: Device- and lead-related adverse events

Study Author, Year PMID | N | Mean Followup | Device Type [Model]^*^ | Device-Related Adverse Events | % | /100 Pt-Y | Lead-Related Adverse Events | % | /100 Pt-Y
ICD arms from RCTs^†^
MADIT II Moss, 2002 11907286 | 742 | 20 mo | ICD [Guidant] | -- | | | Lead problems requiring surgical intervention | 1.8% | --
Other Studies
Hauser, 2002 22396584 | 1,675 | 86 mo maximum | ICD [Quattro Secure 6947] | -- | | | Lead failure | 1.4% | --
Sengupta, 2012 22314669 | 940 | 70 mo | Single- or dual-chamber ICD or CRT-D | Device malfunction (P<0.001 vs. advisory) | 1.6% | --
Thijssen,2012 22094073 | 3,194^‡^ | 49 mo | Single- or dual-chamber ICD or CRT-D [Multiple] § | System malfunction requiring replacement | 2.6% | -- | --
Bode, 2012 22753865 | 903 | 49 mo | ICD [High voltage RV lead] | -- | | | High voltage lead defect | 7.0% | --
Brullman, 2012 22154315 | 936║ | 43 mo | Single- or dual-chamber ICD or CRT-D | -- | | | Lead revision | 19% | --
Van Rees, 2012 22352338 | 1,602^‡^ | 41 mo | ICD^¶^ | -- | | | Lead failure | 3.9% | 1.14
Van Rees, 2012 22352338 | 1,602^‡^ | 41 mo | ICD^¶^ | -- | | | Cumulative lead failure at 8 yr | 11.5% | --
Morrison, 2011 21737019 | 1,641 | 40 mo | ICD or CRT-D [Quattro Secure 6947] | -- | | | Lead survival: 98.7% | -- | --
RAFT Parkash, 2012 23159551 | 969 | 39 mo median | ICD or CRT-D | -- | | | Lead failure | 0.2% | --
Tsai, 2010 19262366 | 1,060 | 38 mo | ICD | ICD malfunction requiring replacement | 0.5% | -- | Lead repositioning required | 0.3% | --
Tsai, 2010 19262366 | 1,060 | 38 mo | ICD | ICD malfunction requiring replacement | 0.5% | -- | Lead fracture requiring revision | 3.4% | --
Borleffs, 2009 19808497 | 2,068^‡^ | 36 mo | Single- or dual- chamber ICD or CRT-D [Multiple] § | -- | | | Lead failure | 3.8% | 1.4^**^
Borleffs, 2009 19808497 | 2,068^‡^ | 36 mo | Single- or dual- chamber ICD or CRT-D [Multiple] § | -- | | | Lead dislodgement within 6 mo | 0.6%^††^ | --
Dichtl, 2011 21678454 | 1,117║ | 35 mo^††^ | Single- or dual-chamber ICD or CRT-D | -- | | | Lead dysfunction (undefined) | 16.5% | --
Porterfield, 2010 19925609 | 15,387 | 18.0 mo | ICD or CRT-D [St. Jude Riata leads 1500 or 7000 series] | -- | | | Total lead-related AE^‡‡^ | 3.6%^§§^ | --
Porterfield, 2010 19925609 | 15,387 | 18.0 mo | ICD or CRT-D [St. Jude Riata leads 1500 or 7000 series] | -- | | | Lead dislodgement | 0.9% | --
Porterfield, 2010 19925609 | 15,387 | 18.0 mo | ICD or CRT-D [St. Jude Riata leads 1500 or 7000 series] | -- | | | Lead malfunction, electrical ║║ | 0.5%
Porterfield, 2010 19925609 | 15,387 | 18.0 mo | ICD or CRT-D [St. Jude Riata leads 1500 or 7000 series] | -- | | | Lead malfunction, other^¶¶^ | 1.9% | --
Landolina, 2011 21576653 | 3,253 | 18 mo median | Single- or dual- chamber ICD or CRT-D [Medtronic] | ICD surgical revision | 6.4%^††^ | 5.2^***^ | Lead malfunction | -- | 1.2^†††^
Landolina, 2011 21576653 | 3,253 | 18 mo median | Single- or dual- chamber ICD or CRT-D [Medtronic] | ICD surgical revision | 6.4%^††^ | 5.2^***^ | Lead dislodgement | -- | 2.8^†††^
Charytan, 2011 21664735 | 9,528 ESRD | 16.8 mo^††^ | ICD or CRT-D | Generator replacement | -- | 3.9 | Lead removal / change | -- | 3.4
TRUST Varma, 2010 20716717 | 1,339 | 13.4 mo^††^ | Single- or dual- chamber ICD [Biotronik] ‡‡‡ | ICD replacement | <0.1%^††^ | 0.1 | Lead revision | 0.9%^††^ | 0.8
TRUST Varma, 2010 20716717 | 1,339 | 13.4 mo^††^ | Single- or dual- chamber ICD [Biotronik] ‡‡‡ | ICD replacement | <0.1%^††^ | 0.1 | Lead replacement | 0.4%^††^ | 0.34
TRUST Varma, 2010 20716717 | 1,339 | 13.4 mo^††^ | Single- or dual- chamber ICD [Biotronik] ‡‡‡ | ICD replacement | <0.1%^††^ | 0.1 | ICD explanted due to lead fracture | <0.1% | 0.07
Lyman, 2011 21795298 | 38,992 | 3 mo | ICD | ICD mechanical complications | 4.2% | -- | --
Lyman, 2011 21795298 | 38,992 | 12 mo | ICD | ICD revision procedure | 2.2% | -- | --
Gradaus, 2003 12914630 | 2,554 | 2.6 mo | Single- or dual-chamber ICD | ICD dislocation | 1.9% | -- | Lead dislocation | 1.4% | --
MacFadden, 2012 22312139 | 4,830 | 1.5 mo^††^ | Single- or dual chamber ICD or CRT-D | -- | | | Lead replacement | 1.0%^††^ | --
MacFadden, 2012 22312139 | 4,830 | 1.5 mo^††^ | Single- or dual chamber ICD or CRT-D | -- | | | Lead repositioning, any | 1.2%^††^ | --
MacFadden, 2012 22312139 | 4,830 | 1.5 mo^††^ | Single- or dual chamber ICD or CRT-D | -- | | | Lead dislodgement, repositioned | 0.6%^††^ | --
MacFadden, 2012 22312139 | 4,830 | 1.5 mo^††^ | Single- or dual chamber ICD or CRT-D | -- | | | Lead dislodgement, not repositioned | 2.5%^††^ | --

AE=adverse event; CRT-D=cardiac resynchronization therapy-defibrillator; ESRD=end stage renal disease; ICD=implantable cardioverter-defibrillator; mo=month; PMID=PubMed ID; Pt-y=Patient-year; RV=right ventricular; y=year. For study name acronyms see Appendix Table 16.

* Generator and/or lead models noted if documented.

† Includes ICD arm of trials from Key Question 1 with ≥500 patients with ICDs.

‡ Likely patient overlap between Thijssen,2012 [22094073], Borleffs [19808497] and Van Rees [22352338]. All data from Leiden University Medical Center Cardiology Information System (EPD-Vision).

§ Implanted systems were manufactured by Biotronik, Medtronic, Boston Scientific/Guidant, and St. Jude Medical/Ventritex

║ Likely patient overlap between Brullman [22154315] and Ditchl [21678454].

¶ These analyses exclude patients receiving Sprint Fidelis or Riata leads.

** per 100 lead-years.

†† calculated

‡‡ Includes perforations (0.38%), dislodgements, electrical malfunctions and other lead-related AEs.

§§ 573 events in 561 patients

║║ Insulation damage, conductor fracture, impedance issues

¶¶ Sensing issues, elevated threshold, loss of capture, diaphragmatic simulation, High DFT, unclassified

*** 220 events in 210 patients. From figure.

††† Includes 44 lead failures among 1985 patients with Sprint Fidelis (1.5 per 100 pt-yrs.)

‡‡‡ Biotronik generators capable of automatic remote home monitoring (Lumax 300 DR-T (1.3%), Lumax 300 VR-T (1.1%), Lumax 340 DR-T (22.2%), Lumax 340 VR-T (11.9%), Lumos DR-T (33.9%), Lumos

Appendix Table 20 Late adverse events: Device- and lead-related adverse events in patients with advisory leads or devices

Study Author, Year PMID | N | Mean Followup | Device Type [Model]^*^ | Device- or Lead-Related Adverse Events | %
Advisory Devices
Sengupta, 2012 22314669 | 704 | 70 mo | Single- or dual-chamber ICD or CRT-D [Advisory] | Device malfunction | 6.1% †
Advisory Leads
Hauser, 2002 22396584 | 1,035 | 86 mo maximum | ICD [Fidelis leads 6931, 6948, 6949] | Lead failure | 8.1%
Tzogias, 2012 22314669, US | 971 | 46 mo | Single- or dual-chamber ICD or CRT-D [Fidelis 6949 leads] | Lead failure | 7.1%
Tzogias, 2012 22314669, US | 971 | 46 mo | Single- or dual-chamber ICD or CRT-D [Fidelis 6949 leads] | Lead fracture leading to failure | 6.8% ‡
Cheung, 2012 22923271 | 602 | 42 mo median | ICD [Fidelis leads models 6949, 6931, 6948] | Lead failure | 8.4%
Birnie, 2012 22311781 | 3,169 | 41 mo median | ICD [Fidelis leads] | Lead failure | 7.9%
RAFT Parkash, 2012 23159551 | 818 | 39 mo median | ICD or CRT-D [Fidelis leads] | Lead failure | 5.5%^§^
RAFT Parkash, 2012 23159551 | 818 | 39 mo median | ICD or CRT-D [Fidelis leads] | Lead fracture | 1.65% per year
Morrison, 2011 21737019 | 1,030 | 34 mo | ICD or CRT-D [Fidelis leads 6931, 6948, 6949] | Lead survival: 87.0%║ | --
Brumberg, 2012 22519559 | 621 | 32 mo | Single- or dual-chamber ICD or CRT-D [Fidelis leads] | Lead malfunction | 8.4% ‡

CRT-D=cardiac resynchronization therapy-defibrillator; ICD=implantable cardioverter-defibrillator; mo=month; PMID=PubMed ID.

* Generator and/or lead models noted if documented.

† 4.0% advisory-related malfunctions. Device malfunction is patients with non-advisory devices: 1.6% (see Appendix Table 18). P<0.001 advisory versus non-advisory devices.

‡ Calculated

§ Lead failure in patients with non-Fidelis leads: 0.2%. (see Appendix Table 18A). P<0.0001 Fidelis vs. non-Fidelis leads.

║ Lead survival in patients with non-advisory leads: 98.7% (see Appendix Table 18A). P<0.001 advisory versus non-advisory leads.

Appendix Table 21 Late adverse events: Infection and deep vein thrombosis

Study Author, Year PMID | N | Mean Followup | Device Type [Model]^*^ | Infection | % | /100 Pt-Y | Thrombosis | %
ICD arms from RCTs^†^
SCD-HeFT Freudenberger, 2007 17485579 | 681 | 45.5 mo Median | Single-chamber ICD [Medtronic 7223] | -- | | | Any thrombo-embolic event | 2.9%
MADIT II Moss, 2002, 11907286 | 742 | 20 mo | ICD [Guidant] | Non-fatal infection requiring surgical intervention | 0.7% | -- | --
Other Studies
Thijssen, 2012 22094073 | 3,194^§^ | 49 mo | Single- or dual-chamber ICD or CRT-D [Multiple║] | Infection requiring ICD replacement | 3.7% | -- | --
Bode, 2012 22753865 | 903 | 49 mo | ICD | -- | | | Symptomatic subclavian venous thrombosis | 0.9%
Van Rees, 2012 22352338 | 1,602^§^ | 41 mo | ICD^¶^ | Infection (undefined) | 2.7% | | --
Tsai, 2010 19262366 | 1,060 | 38 mo | ICD | Lead infection requiring antibiotics | 0.5% | -- | --
Borleffs, 2009 19808497 | 2,068^§^ | 36 mo | Single- or dual-chamber ICD or CRT-D [Multiple║] | Pocket infection requiring lead removal | 1.7%^*,*^ | -- | --
De Bie, 2012 22056722 | 2,476^§^ | 30 mo median | ICD or CRT-D [Multiple║] | Infection requiring device and lead removal | 2.6% | -- | --
Landolina, 2011 21576653 | 3,253 | 18 mo median | Single- or dual- chamber ICD or CRT-D [Medtronic] | Incisional infection treated conservatively | -- | 0.3^*,*^ | --
Landolina, 2011 21576653 | 3,253 | 18 mo median | Single- or dual- chamber ICD or CRT-D [Medtronic] | Infection requiring system removal | -- | 0.7^††^ | --
Charytan, 2011 21664735 | 9,528 ESRD | 16.8 mo^*,*^ | ICD or CRT-D | Severe infection during 1^st^ year ‡‡ | -- | 98.8 | --
Charytan, 2011 21664735 | 9,528 ESRD | 16.8 mo^*,*^ | ICD or CRT-D | Subsequent years (N=4,552) | -- | 63.9 | --
Charytan, 2011 21664735 | 9,528 ESRD | 16.8 mo^*,*^ | ICD or CRT-D | Device infection | -- | 4.2 | --
Gradaus, 2003 12914630 | 1,033 | 12 mo | Single- or dual-chamber ICD | Infection of ICD device | 0.9%^*,*^ | -- | --
Remmelts, 2009 19325900 | 667 | 10 mo^*,*^ | Single- or dual-chamber ICD or CRT-D | Pocket infection with or without bacteremia or ICD-related endocarditis | 1.0%^§§^ | 1.2 | --
Lyman, 2011 21795298 | 38,992 | 3 mo | ICD | Infection | 1.2% | -- | Deep venous thrombosis | 1.0%
Lee, 2010 20170816 | 3,340 | 1.5 mo | Single- or dual- chamber ICD or CRT-D | Pocket infection requiring debridement | 1.0% | -- | Subclavian venous thrombosis | 0.2%
Lee, 2010 20170816 | 3,340 | 1.5 mo | Single- or dual- chamber ICD or CRT-D | Sepsis | 0.2% | -- | Subclavian venous thrombosis | 0.2%

CRT-D=cardiac resynchronization therapy-defibrillator; ESRD=end stage renal disease; ICD=implantable cardioverter-defibrillator; MADIT II=Multicenter Automatic Defibrillator Implantation Trial II; mo=month; PMID=PubMed ID; Pt-Y=patient-year; SCD-HeFT= Sudden Cardiac Death in Heart Failure Trial.

* Generator and/or lead models noted if documented.

† Includes ICD arm of trials from key question 1 with ≥500 patients with ICDs.

‡ Excludes patients with atrial fibrillation or flutter at baseline.

§ Likely patient overlap between Borleffs [19808497], de Bie [22056722], Thijssen [22094073] and Van Rees [22352338]. All data from Leiden University Medical Center Cardiology Information System (EPD-Vision).

║ Implanted systems were manufactured by Biotronik, Medtronic, Boston Scientific/Guidant, and St. Jude Medical/Ventritex

¶ Excludes patients receiving Sprint Fidelis or Riata leads

** Calculated

†† From figure

‡‡ Severe infection defined as any of the following: episodes coded as device infections, postoperative infections, bacteremia, septicemia, and all episodes in which patients received intravenous vancomycin.

§§ Data calculated. Includes N=2 (0.3%) post-operative infections.

Appendix Table 22 P values for comparisons of late adverse events and inappropriate shock by patient subgroup

Adverse Event | Primary vs. Secondary Prevention | LVEF | NYHA Class IV vs. III | Dual- vs. Single-chamber ICD | Single-chamber ICD vs. CRT-D | Age | Female^*^ | DM | Lower Physician Volume | Lower Hospital Volume | OR vs. CCL
Inappropriate shocks | NS (A, E, F,U) P<0.001 (M) worse for secondary | NS (P)^†^ | NS (P) | P=0.02 (C) worse for single-chamber NS (A, I) | NS (A) | P<0.01 (A), P<0.04 (K) P<0.05 (Q,M^‡^) nd (D) worse for younger | NS (A, M, O) | P=0.0076 (D) NS (J,M) | -- | -- | --
Surgical intervention / revision | NS (G^§^)║ | -- | -- | P=0.004 (H) worse for dual-chamber | P<0.001 (H) worse for CRT-D | -- | -- | -- | NS (N) | P<0.01 (N)^¶^ | --
Lead dislodgement, requiring intervention or undefined | NS (H^**^) | -- | -- | -- | -- | NS (H^**^,Q) | NS (H^**^, O^§^) | NS (J) | -- | -- | --
Lead dislodgement, no intervention | -- | -- | -- | -- | -- | -- | P=0.003 (O) | -- | -- | -- | --
Lead malfunction / replacement / failure | -- | -- | -- | -- | -- | NS (Q) | P<0.001 (O) | -- | -- | -- | --
Recalled lead malfunction / failure | NS (R, S, T) | P=0.026 (R) worse for higher; NS (S, T, V)^††^ | NS (V) | NS (L) NS (T) ‡‡ | P=0.0021 worse for CRT (V^§§^); NS (L, T^‡‡^) | P=0.016 worse for older (R); NS (L, T, V) | P=0.028 (L) P=0.005 (R) P=0.02 (S), NS (T, V) | NS (T) | -- | -- | --
Infection | NS (H) | -- | -- | nd (B^§^) | -- | NS (H,Q) | NS (H,O^§^) | NS (H, J) | NS (N) | NS (N) | nd (B^§^)
Deep vein thrombosis | -- | -- | -- | -- | -- | -- | P=0.004 (O^§^) | -- | P<0.01 (N)^¶^ | NS (N) | --
Number of papers (reporting statistics) | 10 (10) | 5 (5) | 2 (2) | 7 (6) | 5 (5) | 10 (9) | 9 (9) | 5 (5) | 1 (1) | 1 (1) | 1 (0)

A-R in parentheses indicate specific studies. (See Study Key, below)

P values <0.05 indicate statistically higher rates of AE in subgroup, unless otherwise noted. NS indicates no statistical difference in AE between subgroups. nd indicates paper reported rates of AE by subgroup but did not report statistical comparison between groups.

CCL=cardiac catheterization lab; CRT-D=cardiac resynchronization therapy-defibrillator; DM=diabetes mellitus; ICD=implantable cardioverter-defibrillator; LVEF=left ventricular ejection fraction; MADIT II=Multicenter Automatic Defibrillator Implantation Trial II; MADIT-CRT=Multicenter Automatic Defibrillator Implantation Trial with Cardiac Resynchronization Therapy; NYHA=New York Heart Association; OR=operating room; PMID=PubMed ID

* Adverse events are higher or NS different in females compared with males.

† LVEF 31-35% vs. ≤30%

‡ Paper reports hazard ratio with confidence interval that does not cross 1.0.

§ Less than 10 events in at least one subgroup.

║ Patients receiving ICDs for primary prevention compared with “other indications”.

¶ Higher rates of AEs with lower ICD implantation volume.

** Left ventricular lead dislodgement in CRT-D patients

†† Worse for each 10% absolute increase in LVEF (R); not statistically significantly different for continuous LVEF (S, T) or LVEF >23% vs. ≤23% (V).

‡‡ No statistically significant difference across three subgroups: single-chamber ICD, dual-chamber ICD and CRT-D.

§§ Single- or dual-chamber ICD vs. CRT-D

[underlined: Study Key] (Author, Year, PMID)
A | Van Rees, 2011, 21272746
B | Remmelts, 2009, 19325900
C | Larsen, 2010, 20186244
D | Sandesara, 2011, 21086086
E | Van Welsenes, 2011, 21208947
F | Ditchl, 2011, 21678454
G | Varma, 2010, 20716717
H | Landolina, 2011, 21576653
I | MADIT II, Berenbom, 2005, 16255753
J | MADIT-CRT, Martin, 2011, 21350054
K | Brullman, 2012, 22154315
L | Brumberg, 2012, 22519559
M | Kleemann, 2012, 2232331
N | Lyman, 2011, 21795298
O | McFadden, 2012, 22312139
P | Sweeney, 2012, 22387371
Q | Van Rees, 2012, 21920909
R | Birnie, 2012, 22311781
S | Cheung, 2012, 22923271
T | Tzogias, 2012, 22314669
U | Sweeney, 2005, 15927965
V | RAFT, Parkash, 2012, 23159551

Appendix Table 23 Eligibility criteria

Study Author, Year PMID Country | Study type (# of centers) | Total N (Study duration) | Inclusion | | | | | | Specification regarding:
Study Author, Year PMID Country | Study type (# of centers) | Total N (Study duration) | Age, y | Etiology | 1° prevention | LVEF | NYHA | QRS interval | MI | Revascularization excluding CABG | CABG
Studies of patients with ischemic cardiomyopathy and remote MI (>30 or 40 days)
ICD vs. no ICD
MADIT Moss, 1996 8960472 US and EU | RCT (32) | 196 (5 y, mean 27 mo) | 25-80 | Ischemic | Yes | ≤35 | I, II, III | nd | Inc: Q-wave or enzyme-positive MI ≥3 wk | Exc: Coronary angioplasty within the past 3 mo | Exc: CABG within the past 2 mo
MADIT II Moss, 2002 11907286 US and EU | RCT (76) | 1232 (mean 20 mo; range 6 d-53 mo) | >21 | Ischemic | Yes | ≤30 | I, II, III | nd | Inc: MI ≥1 mo Exc: MI within the past mo | Exc: Coronary revascularization within prior 3 mo | nd
Studies of patients with nonischemic cardiomyopathy
ICD vs. no ICD
AMIOVIRT Strickberger, 2003 12767651 US | RCT (10) | 103 (5 y) | ≥18 | Nonischemic | Yes | ≤35 | I, II, III | nd | nd | nd | nd
CAT Bansch, 2002 11914254 Germany | RCT (15) | 104 (6 y) | 18-70 | Nonischemic | Yes | ≤30 | II, III | nd | Exc: History of prior MI | nd | nd
DEFINITE Kadish, 2004 15152060 US | RCT (25) | 458 (5 y; mean 2.4 y) | nd | Nonischemic | Yes | <36 | I, II, III | nd | nd | nd | nd
Fonarow, 2000 10760339 US | Retrospective cohort (1) | 147 (mean 22 mo) | nd | Nonischemic | Yes | <35 | III, IV | nd | nd | nd | nd
Studies of patients with mixed ischemic and nonischemic cardiomyopathy
ICD vs. no ICD
Chan, 2009 20031808 US | Prospective cohort (7) | 965 (5 y) | ≥18 | Ischemic, nonischemic | Yes | ≤35 | nd | >120 ms | Inc: MI of ≥30 d | nd | nd
COMPANION Bristow, 2004 15152059 US | RCT (128) | 1520 (3.0 y; median 14 mo) | nd | Ischemic, nonischemic | Yes | ≤35 | III, IV | ≥120 ms | nd | nd | nd
Mezu, 2011 21640321 US | Retrospective cohort (1) | 152 (4 y; mean 2.3 y) | ≥80 | Ischemic, nonischemic | Yes | ≤35 | I, II, III (class I only if prior MI) | nd | nd | nd | nd
OPTIMIZE-HF and GWTG-HF Hernandez, 2010 20009044 US | Retrospective cohort, registry (nd) | 4685 (3 y) | 65-84 | Ischemic, nonischemic | Yes | ≤35 | nd | nd | nd | nd | nd
SCD-HeFT Bardy, 2005 15659722 US | RCT (nd) | 2521 (6 y; median 46 mo) | >18 | Ischemic, nonischemic | Yes | ≤35 | II, III | nd | nd | nd | nd
ICD vs. CRT-D
Diab, 2011 21700757 UK | RCT (1) | 73 (6 mo) | nd | Ischemic, nonischemic | nd | ≤35 | III, IV | ≥120 ms | nd | nd | nd
MADIT-CRT Moss, 2009 19723701 US, Canada, EU | RCT (110) | 1820 (4 y; mean 2.4 y) | ≥21 | Ischemic, nonischemic | nd | ≤30 | I, II | ≥130 ms | Exc: MI within 3 mo | Exc: PCI within 3 mo | Exc: Previous CABG within 3 mo
RAFT Tang 2010 21073365 Multi | RCT | 1798 (mean 40 mo) | nd | Ischemic, nonischemic | nd (86% were primary prevention) | ≤30 | II, III | Intrinsic: ≥120 ms; Paced: ≥200ms | nd | nd | nd
Studies of patients with ischemic cardiomyopathy and recent MI (<30 days) or revascularization
ICD vs. no ICD
CABG-Patch Bigger, 1997 9371853 US and Germany | RCT (37) | 900 (4 y; mean 2.7 y) | <80 | Ischemic | Yes | <36 | nd | ≥114 ms | nd | nd | Inc: Scheduled for CABG Exc: Emergency CABG
DINAMIT Hohnloser, 2004 15590950 Multi | RCT (73) | 674 (4 y; mean 2.5 y) | 18-80 | Ischemic | Yes | ≤35 | I, II, III | nd | Inc: MI (6-40 d prior) | Exc: 2-vessel PCI since the qualifying MI | Exc: CABG since the qualifying MI or planned within 4 wk
IRIS Steinbeck, 2009 19812399 Germany | RCT (nd) | 898 (6 y; mean 37 mo) | 18-80 | Ischemic | Yes | ≤40 | I, II, III | nd | Inc: MI (5-31 d prior) | nd | Exc: An indication for CABG
ICD vs. CRT-D
MENDMI Chung, 2010 20852059 US | RCT (29) | 80 (12 mo) | nd | Ischemic | nd | ≤35 | I, II, III | <120 ms | Inc: Anterior MI 3-14 d | nd | Exc: CABG 30 d before or after enrollment

1°=primary, CABG=coronary artery bypass graft, EU=Europe, ICD=implantable cardiac defibrillator, LVEF=left ventricular ejection fraction, MI=myocardial infarction, mo=month, ms=millisecond, nd=not documented, NYHA=New York Heart Association, RCT=randomized controlled trial, UK, United Kingdom, US=United States, wk=week, y=year For study names, see Appendix Table 1.