# Excluded Studies

The 223 studies excluded after full-text review are listed in alphabetical order by first author under each main reason for exclusion (bold headings): adverse event paper published before 2002 (n=10), <500 adverse events (n=8), mixed primary and secondary prevention and no adverse effect (n=33), no outcomes of interest (n=28), and not comparison of interest (n=6), not intervention of interest (n=3), outcome numerator or denominator unclear (n=8), protocol (not full article) (n=5), review/editorial (n=4), secondary prevention (n=31), not study design of interest (n=59), wrong population (n=24), and other (n=4). PMIDs are given at the end of each reference, when available.

## Adverse Event Paper Published Before 2002 (n=10)

1 Pacifico A, Johnson JW, Stanton MS, et al. Comparison of results in two implantable defibrillators. Jewel 7219D Investigators. Am J Cardiol. Oct. 1. 1998;82(7):875-80. [pmid: 9781970].
2 Hoffmann E, Steinbeck G. Experience with pectoral versus abdominal implantation of a small defibrillator. A multicenter comparison in 778 patients. European Jewel Investigators. Eur Heart J. Jul. 1998;19(7):1085-98. [pmid: 9717045].
3 Rosenqvist M, Beyer T, Block M, et al. Adverse events with transvenous implantable cardioverter-defibrillators: a prospective multicenter study. European 7219 Jewel ICD investigators. Circulation. Aug. 18. 1998;98(7):663-70. [pmid: 9715859].
4 Smith PN, Vidaillet HJ, Hayes JJ, et al. Infections with nonthoracotomy implantable cardioverter defibrillators: can these be prevented? Endotak Lead Clinical Investigators. Pacing Clin Electrophysiol. Jan. 1998;21(1 Pt 1):42-55. [pmid: 9474647].
5 Narasimhan C, Dhala A, Axtell K, et al. Comparison of outcome of implantable cardioverter defibrillator implantation in patients with severe versus moderately severe left ventricular dysfunction secondary to atherosclerotic coronary artery disease. Am J Cardiol. Nov. 15. 1997;80(10):1305-08. [pmid: 9388103].
6 Panotopoulos PT, Axtell K, Anderson AJ, et al. Efficacy of the implantable cardioverter-defibrillator in the elderly. J Am Coll Cardiol. Mar. 1. 1997;29(3):556-60. [pmid: 9060893].
7 Gold MR, Peters RW, Johnson JW, et al. Complications associated with pectoral implantation of cardioverter defibrillators. World-Wide Jewel Investigators. Pacing Clin Electrophysiol. Jan. 1997;20(1 Pt 2):208-11. [pmid: 9121991].
8 Gallik DM, Ben-Zur UM, Gross JN, et al. Lead fracture in cephalic versus subclavian approach with transvenous implantable cardioverter defibrillator systems. Pacing Clin Electrophysiol. Jul. 1996;19(7):1089-94. [pmid: 8823837].
9 Zipes DP, Roberts D. Results of the international study of the implantable pacemaker cardioverter-defibrillator. A comparison of epicardial and endocardial lead systems. The Pacemaker-Cardioverter-Defibrillator Investigators. Circulation. Jul. 1. 1995;92(1):59-65. [pmid: 7788918].
10 Mosteller RD, Lehmann MH, Thomas AC, et al. Operative mortality with implantation of the automatic cardioverter-defibrillator. Am J Cardiol. Nov. 15. 1991;68(13):1340-45. [pmid: 1951123].

## Adverse Events N<500 (n=13)

1 Holst AG, Jensen HK, Eschen O, et al. Low disease prevalence and inappropriate implantable cardioverter defibrillator shock rate in Brugada syndrome: a nationwide study. Europace. Jul. 2012;14(7):1025-29. [pmid: 22286273].
2 Yu JB, Yang B, Xu DJ, et al. Impact of metoprolol use in the treatment of patients with electrical-storm after cardioverter defibrillators implantation. Zhonghua Xin Xue Guan Bing Za Zhi. Aug. 2011;39(8):717-20. [pmid: 22169417].
3 Forleo GB, Tesauro M, Panattoni G, et al. Impact of continuous intracardiac ST-segment monitoring on mid-term outcomes of ICD-implanted patients with coronary artery disease. Early results of a prospective comparison with conventional ICD outcomes. Heart. Mar. 2012;98(5):402-07. [pmid: 22115985].
4 Gojkovic O, Aliot EM, Capucci A, et al. Celivarone in patients with an implantable cardioverter-defibrillator: adjunctive therapy for the reduction of ventricular arrhythmia-triggered implantable cardioverter-defibrillator interventions. Heart Rhythm. Feb. 2012;9(2):217-24. [pmid: 21978965].
5 McLeod CJ, Shen WK, Rea RF, et al. Differential outcome of cardiac resynchronization therapy in ischemic cardiomyopathy and idiopathic dilated cardiomyopathy. Heart Rhythm. Mar. 2011;8(3):377-82. [pmid: 21070886].
6 Kettering K, Mewis C, Dornberger V, et al. Long-term experience with subcutaneous ICD leads: a comparison among three different types of subcutaneous leads. Pacing Clin Electrophysiol. Oct. 2004;27(10):1355-61. [pmid: 15511244].
7 Sandstedt B, Kennergren C, Schaumann A, et al. Short- and long-term performance of a tripolar down-sized single lead for implantable cardioverter defibrillator treatment: a randomized prospective European multicenter study. European Endotak DSP Investigator Group. Pacing Clin Electrophysiol. Nov. 1998;21(11 Pt 1):2087-94. [pmid: 9826861].
8 Mehta D, Nayak HM, Singson M, et al. Late complications in patients with pectoral defibrillator implants with transvenous defibrillator lead systems: high incidence of insulation breakdown. Pacing Clin Electrophysiol. Oct. 1998;21(10):1893-900. [pmid: 9793085].
9 Lelakowski J, Piekarz J, Rydlewska A, et al. Determinants of patient survival rate after implantation of a cardioverter-defibrillator without resynchronisation capability. Kardiol Pol. 2012;70(11):1099-110. [pmid: 23180517].
10 Codner P, Nevzorov R, Kusniec J, et al. Implantable cardioverter defibrillator with and without defibrillation threshold testing. Isr Med Assoc J. Jun. 2012;14(6):343-46. [pmid: 22891393].
11 Aschenbrenner T, Brockmeier J, Bramlage P, et al. Improved survival of patients with coronary artery disease and low ejection fraction with ICD implantation versus conventional therapy in a real world survey. BMC Res Notes. 2012;5:382. [pmid: 22840219].
12 Lovelock JD, Patel A, Mengistu A, et al. Generator exchange is associated with an increased rate of Sprint Fidelis lead failure. Heart Rhythm. Oct. 2012;9(10):1615-18. [pmid: 22683747].
13 Clementy N, Pierre B, Lallemand B, et al. Long-term follow-up on high-rate cutoff programming for implantable cardioverter defibrillators in primary prevention patients with left ventricular systolic dysfunction. Europace. Jul. 2012;14(7):968-74. [pmid: 22389416].

## Mixed Primary and Secondary Prevention, No Adverse Effect (n=33)

1 Pedersen SS, Tekle FB, Hoogwegt MT, et al. Shock and patient preimplantation type D personality are associated with poor health status in patients with implantable cardioverter-defibrillator. Circ Cardiovasc Qual Outcomes. May. 2012;5(3):373-80. [pmid: 22570357].
2 Cho EY, von KR, Marten-Mittag B, et al. Determinants and trajectory of phobic anxiety in patients living with an implantable cardioverter defibrillator. Heart. May. 2012;98(10):806-12. [pmid: 22543838].
3 Berg SK, Higgins M, Reilly CM, et al. Sleep quality and sleepiness in persons with implantable cardioverter defibrillators: outcome from a clinical randomized longitudinal trial. Pacing Clin Electrophysiol. Apr. 2012;35(4):431-43. [pmid: 22303998].
4 Shalaby A, Brumberg G, El-Saed A, et al. Mood disorders and outcome in patients receiving cardiac resynchronization therapy. Pacing Clin Electrophysiol. Mar. 2012;35(3):294-301. [pmid: 22229659].
5 Flemme I, Johansson I, Stromberg A. Living with life-saving technology -coping strategies in implantable cardioverter defibrillators recipients. J Clin Nurs. Feb. 2012;21(3-4):311-21. [pmid: 21951323].
6 Habibovic M, van den Broek KC, Alings M, et al. Posttraumatic stress 18 months following cardioverter defibrillator implantation: shocks, anxiety, and personality. Health Psychol. Mar. 2012;31(2):186-93. [pmid: 21806300].
7 Pedersen SS, Hoogwegt MT, Jordaens L, et al. Relation of symptomatic heart failure and psychological status to persistent depression in patients with implantable cardioverter-defibrillator. Am J Cardiol. Jul. 1. 2011;108(1):69-74. [pmid: 21529736].
8 Tzeis S, Kolb C, Baumert J, et al. Effect of depression on mortality in implantable cardioverter defibrillator recipients--findings from the prospective LICAD study. Pacing Clin Electrophysiol. Aug. 2011;34(8):991-97. [pmid: 21438895].
9 Chair SY, Lee CK, Choi KC, et al. Quality of life outcomes in chinese patients with implantable cardioverter defibrillators. Pacing Clin Electrophysiol. Jul. 2011;34(7):858-67. [pmid: 21410723].
10 Heatherly SJ, Simmons T, Fitzgerald DM, et al. Psychological effects of implantable cardioverter-defibrillator leads under advisory. Pacing Clin Electrophysiol. Jun. 2011;34(6):694-99. [pmid: 21410721].
11 von KR, Baumert J, Kolb C, et al. Chronic posttraumatic stress and its predictors in patients living with an implantable cardioverter defibrillator. J Affect Disord. Jun. 2011;131(1-3):344-52. [pmid: 21195483].
12 Marcus GM, Chan DW, Redberg RF. Recollection of pain due to inappropriate versus appropriate implantable cardioverter-defibrillator shocks. Pacing Clin Electrophysiol. Mar. 2011;34(3):348-53. [pmid: 21077915].
13 Suzuki T, Shiga T, Kuwahara K, et al. Prevalence and persistence of depression in patients with implantable cardioverter defibrillator: a 2-year longitudinal study. Pacing Clin Electrophysiol. Dec. 2010;33(12):1455-61. [pmid: 20946285].
14 Keren A, Sears SF, Nery P, et al. Psychological adjustment in ICD patients living with advisory fidelis leads. J Cardiovasc Electrophysiol. Jan. 2011;22(1):57-63. [pmid: 20731739].
15 Pedersen SS, van den Broek KC, Erdman RA, et al. Pre-implantation implantable cardioverter defibrillator concerns and Type D personality increase the risk of mortality in patients with an implantable cardioverter defibrillator. Europace. Oct. 2010;12(10):1446-52. [pmid: 20719779].
16 Dickerson SS, Kennedy M, Wu YW, et al. Factors related to quality-of-life pattern changes in recipients of implantable defibrillators. Heart Lung. Nov. 2010;39(6):466-76. [pmid: 20561848].
17 Pedersen SS, Theuns DA, Jordaens L, et al. Course of anxiety and device-related concerns in implantable cardioverter defibrillator patients the first year post implantation. Europace. Aug. 2010;12(8):1119-26. [pmid: 20507853].
18 Kapa S, Rotondi-Trevisan D, Mariano Z, et al. Psychopathology in patients with ICDs over time: results of a prospective study. Pacing Clin Electrophysiol. Feb. 2010;33(2):198-208. [pmid: 19930108].
19 Pedersen SS, den Broek KC, Theuns DA, et al. Risk of chronic anxiety in implantable defibrillator patients: a multi-center study. Int J Cardiol. Mar. 17. 2011;147(3):420-23. [pmid: 19896732].
20 Kim J, Pressler SJ, Welch JL, et al. Validity and reliability of the chronic heart failure questionnaire mastery subscale in patients with defibrillators. West J Nurs Res. Dec. 2009;31(8):1057-75. [pmid: 19783791].
21 Pinter A, Mangat I, Korley V, et al. Assessment of resynchronization therapy on functional status and quality of life in patients requiring an implantable defibrillator. Pacing Clin Electrophysiol. Dec. 2009;32(12):1509-19. [pmid: 19765233].
22 Fisher JD, Koulogiannis KP, Lewallen L, et al. The psychological impact of implantable cardioverter-defibrillator recalls and the durable positive effects of counseling. Pacing Clin Electrophysiol. Aug. 2009;32(8):1012-16. [pmid: 19659621].
23 van den Broek KC, Nyklicek I, Van d, V, et al. Risk of ventricular arrhythmia after implantable defibrillator treatment in anxious type D patients. J Am Coll Cardiol. Aug. 4. 2009;54(6):531-37. [pmid: 19643315].
24 Pandya K, Patel MB, Natla J, et al. Predictors of hemodynamic compromise with propofol during defibrillator implantation: a single center experience. J Interv Card Electrophysiol. Aug. 2009;25(2):145-51. [pmid: 19263205].
25 Bilge AK, Ozben B, Demircan S, et al. Depression and anxiety status of patients with implantable cardioverter defibrillator and precipitating factors. Pacing Clin Electrophysiol. Jun. 2006;29(6):619-26. [pmid: 16784428].
26 Wathen MS, DeGroot PJ, Sweeney MO, et al. Prospective randomized multicenter trial of empirical antitachycardia pacing versus shocks for spontaneous rapid ventricular tachycardia in patients with implantable cardioverter-defibrillators: Pacing Fast Ventricular Tachycardia Reduces Shock Therapies (PainFREE Rx II) trial results. Circulation. Oct. 26. 2004;110(17):2591-96. [pmid: 15492306].
27 Pedersen SS, van Domburg RT, Theuns DA, et al. Type D personality is associated with increased anxiety and depressive symptoms in patients with an implantable cardioverter defibrillator and their partners. Psychosom Med. Sep. 2004;66(5):714-19. [pmid: 15385696].
28 Shukla HH, Flaker GC, Jayam V, et al. High defibrillation thresholds in transvenous biphasic implantable defibrillators: clinical predictors and prognostic implications. Pacing Clin Electrophysiol. Jan. 2003;26(1 Pt 1):44-48. [pmid: 12685138].
29 Godemann F, Ahrens B, Behrens S, et al. Classic conditioning and dysfunctional cognitions in patients with panic disorder and agoraphobia treated with an implantable cardioverter/defibrillator. Psychosom Med. Mar. 2001;63(2):231-38. [pmid: 11292270].
30 Duru F, Buchi S, Klaghofer R, et al. How different from pacemaker patients are recipients of implantable cardioverter-defibrillators with respect to psychosocial adaptation, affective disorders, and quality of life?. Heart. Apr. 2001;85(4):375-79. [pmid: 11250956].
31 Herbst JH, Goodman M, Feldstein S, et al. Health-related quality-of-life assessment of patients with life- threatening ventricular arrhythmias. Pacing Clin Electrophysiol. Jun. 1999;22(6 Pt 1):915-26. [pmid: 10392390].
32 Pacifico A, Hohnloser SH, Williams JH, et al. Prevention of implantable-defibrillator shocks by treatment with sotalol. d,l-Sotalol Implantable Cardioverter-Defibrillator Study Group. N Engl J Med. Jun. 17. 1999;340(24):1855-62. [pmid: 10369848].
33 Dunbar SB, Jenkins LS, Hawthorne M, et al. Mood disturbance in patients with recurrent ventricular dysrhythmia before insertion of implantable cardioverter defibrillator. Heart Lung. Jul. 1996;25(4):253-61. [pmid: 8836741].

## No Outcomes of Interest (n=43)

1 Barsheshet A, Moss AJ, Huang DT, et al. Applicability of a risk score for prediction of the long-term (8-year) benefit of the implantable cardioverter-defibrillator. J Am Coll Cardiol. Jun. 5. 2012;59(23):2075-79. [pmid: 22651863].
2 George J, Barsheshet A, Moss AJ, et al. Effectiveness of cardiac resynchronization therapy in diabetic patients with ischemic and nonischemic cardiomyopathy. Ann Noninvasive Electrocardiol. Jan. 2012;17(1):14-21. [pmid: 22276624].
3 Versteeg H, Starrenburg A, Denollet J, et al. Monitoring device acceptance in implantable cardioverter defibrillator patients using the Florida Patient Acceptance Survey. Pacing Clin Electrophysiol. Mar. 2012;35(3):283-93. [pmid: 22229519].
4 Zecchin M, Merlo M, Pivetta A, et al. How can optimization of medical treatment avoid unnecessary implantable cardioverter-defibrillator implantations in patients with idiopathic dilated cardiomyopathy presenting with “SCD-HeFT criteria?”. Am J Cardiol. Mar. 1. 2012;109(5):729-35. [pmid: 22176998].
5 Sullivan RM, Russo AM, Berg KC, et al. Arrhythmia rate distribution and tachyarrhythmia therapy in an ICD population: results from the INTRINSIC RV trial. Heart Rhythm. Mar. 2012;9(3):351-58. [pmid: 22016074].
6 Hoogwegt MT, Kupper N, Theuns DA, et al. Beta-blocker therapy is not associated with symptoms of depression and anxiety in patients receiving an implantable cardioverter-defibrillator. Europace. Jan. 2012;14(1):74-80. [pmid: 21920910].
7 Sohail MR, Henrikson CA, Braid-Forbes MJ, et al. Mortality and cost associated with cardiovascular implantable electronic device infections. Arch Intern Med. Nov. 14. 2011;171(20):1821-28. [pmid: 21911623].
8 Goldenberg I, Moss AJ, Hall WJ, et al. Predictors of response to cardiac resynchronization therapy in the Multicenter Automatic Defibrillator Implantation Trial with Cardiac Resynchronization Therapy (MADIT-CRT). Circulation. Oct. 4. 2011;124(14):1527-36. [pmid: 21900084].
9 Buber J, Klein H, Moss AJ, et al. Clinical course and outcome of patients enrolled in US and non-US centres in MADIT-CRT. Eur Heart J. Nov. 2011;32(21):2697-704. [pmid: 21642283].
10 Barsheshet A, Goldenberg I, Moss AJ, et al. Effect of elapsed time from coronary revascularization to implantation of a cardioverter defibrillator on long-term survival in the MADIT-II trial. J Cardiovasc Electrophysiol. Nov. 2011;22(11):1237-42. [pmid: 21615813].
11 Pouleur AC, Knappe D, Shah AM, et al. Relationship between improvement in left ventricular dyssynchrony and contractile function and clinical outcome with cardiac resynchronization therapy: the MADIT-CRT trial. Eur Heart J. Jul. 2011;32(14):1720-29. [pmid: 21609974].
12 Knappe D, Pouleur AC, Shah AM, et al. Dyssynchrony, contractile function, and response to cardiac resynchronization therapy. Circ Heart Fail. Jul. 2011;4(4):433-40. [pmid: 21602574].
13 Perrotta L, Pieragnoli P, Ricciardi G, et al. Multicenter experience with implantable defibrillators subject to recall. Pacing Clin Electrophysiol. Aug. 2011;34(8):998-1002. [pmid: 21438897].
14 Rordorf R, Canevese F, Vicentini A, et al. Delayed ICD lead cardiac perforation: comparison of small versus standard-diameter leads implanted in a single center. Pacing Clin Electrophysiol. Apr. 2011;34(4):475-83. [pmid: 21208240].
15 Linde C, Mealing S, Hawkins N, et al. Cost-effectiveness of cardiac resynchronization therapy in patients with asymptomatic to mild heart failure: insights from the European cohort of the REVERSE (Resynchronization Reverses remodeling in Systolic Left Ventricular Dysfunction). Eur Heart J. Jul. 2011;32(13):1631-39. [pmid: 21112898].
16 Barsheshet A, Goldenberg I, Moss AJ, et al. Response to preventive cardiac resynchronization therapy in patients with ischaemic and nonischaemic cardiomyopathy in MADIT-CRT. Eur Heart J. Jul. 2011;32(13):1622-30. [pmid: 21075774].
17 Barsheshet A, Moss AJ, Eldar M, et al. Time-dependent benefit of preventive cardiac resynchronization therapy after myocardial infarction. Eur Heart J. Jul. 2011;32(13):1614-21. [pmid: 21075773].
18 Sauer WH, Lowery CM, Bargas RL, et al. Utility of postoperative testing of implantable cardioverter-defibrillators. Pacing Clin Electrophysiol. Feb. 2011;34(2):186-92. [pmid: 21039640].
19 Goldenberg I, Moss AJ, McNitt S, et al. Relation between renal function and response to cardiac resynchronization therapy in Multicenter Automatic Defibrillator Implantation Trial--Cardiac Resynchronization Therapy (MADIT-CRT). Heart Rhythm. Dec. 2010;7(12):1777-82. [pmid: 20833266].
20 Mohamad T, Jacob S, Kommuri NV, et al. Low referral pattern for implantable defibrillator therapy in a tertiary hospital: referral physician survey and Monte Carlo simulation. Am J Ther. Sep. 2011;18(5):350-54. [pmid: 20335787].
21 Sumner AD, Boehmer JP, Saxon LA, et al. Statin use is associated with improved survival in patients with advanced heart failure receiving resynchronization therapy. Congest Heart Fail. Jul. 2009;15(4):159-64. [pmid: 19627288].
22 Saxon LA, Olshansky B, Volosin K, et al. Influence of left ventricular lead location on outcomes in the COMPANION study. J Cardiovasc Electrophysiol. Jul. 2009;20(7):764-68. [pmid: 19298563].
23 Belardinelli R, Capestro F, Misiani A, et al. Moderate exercise training improves functional capacity, quality of life, and endothelium-dependent vasodilation in chronic heart failure patients with implantable cardioverter defibrillators and cardiac resynchronization therapy. Eur J Cardiovasc Prev Rehabil. Oct. 2006;13(5):818-25. [pmid: 17001224].
24 Steinbeck G, Andresen D, Senges J, et al. Immediate Risk-Stratification Improves Survival (IRIS): study protocol. Europace. Sep. 2004;6(5):392-99. [pmid: 15294263].
25 Lampert R, Joska T, Burg MM, et al. Emotional and physical precipitants of ventricular arrhythmia. Circulation. Oct. 1. 2002;106(14):1800-05. [pmid: 12356633].
26 Schulte B, Sperzel J, Carlsson J, et al. Dual-coil vs single-coil active pectoral implantable defibrillator lead systems: defibrillation energy requirements and probability of defibrillation success at multiples of the defibrillation energy requirements. Europace. Jul. 2001;3(3):177-80. [pmid: 11467457].
27 Whang W, Bigger JT Jr. Diabetes and outcomes of coronary artery bypass graft surgery in patients with severe left ventricular dysfunction: results from The CABG Patch Trial database. The CABG Patch Trial Investigators and Coordinators. J Am Coll Cardiol. Oct. 2000;36(4):1166-72. [pmid: 11028466].
28 Bigger JT Jr., Whang W, Rottman JN, et al. Mechanisms of death in the CABG Patch trial: a randomized trial of implantable cardiac defibrillator prophylaxis in patients at high risk of death after coronary artery bypass graft surgery. Circulation. Mar. 23. 1999;99(11):1416-21. [pmid: 10086963].
29 Masoudi FA, Go AS, Magid DJ, et al. Longitudinal study of implantable cardioverter-defibrillators: methods and clinical characteristics of patients receiving implantable cardioverter-defibrillators for primary prevention in contemporary practice. Circ Cardiovasc Qual Outcomes. Nov. 2012;5(6):e78-e85. [pmid: 23170006].
30 Veazie PJ, Noyes K, Li Q, et al. Cardiac resynchronization and quality of life in patients with minimally symptomatic heart failure. J Am Coll Cardiol. Nov. 6. 2012;60(19):1940-44. [pmid: 23062542].
31 Bilchick KC, Stukenborg GJ, Kamath S, et al. Prediction of mortality in clinical practice for medicare patients undergoing defibrillator implantation for primary prevention of sudden cardiac death. J Am Coll Cardiol. Oct. 23. 2012;60(17):1647-55. [pmid: 23021331].
32 Flo GL, Glenny RW, Kudenchuk PJ, et al. Development and safety of an exercise testing protocol for patients with an implanted cardioverter defibrillator for primary or secondary indication. Cardiopulm Phys Ther J. Sep. 2012;23(3):16-22. [pmid: 22993498].
33 Hsu JC, Solomon SD, Bourgoun M, et al. Predictors of super-response to cardiac resynchronization therapy and associated improvement in clinical outcome: the MADIT-CRT (multicenter automatic defibrillator implantation trial with cardiac resynchronization therapy) study. J Am Coll Cardiol. Jun. 19. 2012;59(25):2366-73. [pmid: 22698490].
34 Barsheshet A, Moss AJ, Huang DT, et al. Applicability of a risk score for prediction of the long-term (8-year) benefit of the implantable cardioverter-defibrillator. J Am Coll Cardiol. Jun. 5. 2012;59(23):2075-79. [pmid: 22651863].
35 Leenhardt A, Defaye P, Mouton E, et al. First inappropriate implantable cardioverter defibrillator therapy is often due to inaccurate device programming: analysis of the French OPERA registry. Europace. Oct. 2012;14(10):1465-74. [pmid: 22547767].
36 Martins RP, Blangy H, Muresan L, et al. Safety and efficacy of programming a high number of antitachycardia pacing attempts for fast ventricular tachycardia: a prospective study. Europace. Oct. 2012;14(10):1457-64. [pmid: 22547765].
37 Brenyo A, Goldenberg I, Moss AJ, et al. Baseline functional capacity and the benefit of cardiac resynchronization therapy in patients with mildly symptomatic heart failure enrolled in MADIT-CRT. Heart Rhythm. Sep. 2012;9(9):1454-59. [pmid: 22521920].
38 Ji SY, Gundewar S, Palma EC. Subclavian venoplasty may reduce implant times and implant failures in the era of increasing device upgrades. Pacing Clin Electrophysiol. Apr. 2012;35(4):444-48. [pmid: 22229641].
39 Sullivan RM, Russo AM, Berg KC, et al. Arrhythmia rate distribution and tachyarrhythmia therapy in an ICD population: results from the INTRINSIC RV trial. Heart Rhythm. Mar. 2012;9(3):351-58. [pmid: 22016074].
40 Kramer DB, Friedman PA, Kallinen LM, et al. Development and validation of a risk score to predict early mortality in recipients of implantable cardioverter-defibrillators. Heart Rhythm. Jan. 2012;9(1):42-46. [pmid: 21893137].
41 Fischer A, Ousdigian KT, Johnson JW, et al. The impact of atrial fibrillation with rapid ventricular rates and device programming on shocks in 106,513 ICD and CRT-D patients. Heart Rhythm. Jan. 2012;9(1):24-31. [pmid: 21835150].
42 Atary JZ, Borleffs CJ, van der Bom JG, et al. Right ventricular stimulation threshold at ICD implant predicts device therapy in primary prevention patients with ischaemic heart disease. Europace. Nov. 2010;12(11):1581-88. [pmid: 20639206].
43 Borleffs CJ, van Rees JB, van Welsenes GH, et al. Prognostic importance of atrial fibrillation in implantable cardioverter-defibrillator patients. J Am Coll Cardiol. Mar. 2. 2010;55(9):879-85. [pmid: 20185038].

## Not Comparison of Interest (n=6)

1 Gilliam FR, Hayes DL, Boehmer JP, et al. Real world evaluation of dual-zone ICD and CRT-D programming compared to single-zone programming: the ALTITUDE REDUCES study. J Cardiovasc Electrophysiol. Sep. 2011;22(9):1023-29. Comparison: programming. [pmid: 21627705].
2 Hauser RG, Maisel WH, Friedman PA, et al. Longevity of Sprint Fidelis implantable cardioverter-defibrillator leads and risk factors for failure: implications for patient management. Circulation. Feb. 1. 2011;123(4):358-63. Comparison: lead 1 vs. lead 2. [pmid: 21242478].
3 Russo AM, Hafley GE, Lee KL, et al. Racial differences in outcome in the Multicenter UnSustained Tachycardia Trial (MUSTT): a comparison of whites versus blacks. Circulation. Jul. 8. 2003;108(1):67-72. Outcome not based on ICD vs. no ICD. [pmid: 12821551].
4 Wilkoff BL, Cook JR, Epstein AE, et al. Dual-chamber pacing or ventricular backup pacing in patients with an implantable defibrillator: the Dual Chamber and VVI Implantable Defibrillator (DAVID) Trial. JAMA. Dec. 25. 2002;288(24):3115-23. Comparison: programming. [pmid: 12495391].
5 Kohn CS, Petrucci RJ, Baessler C, et al. The effect of psychological intervention on patients' long-term adjustment to the ICD: a prospective study. Pacing Clin Electrophysiol. Apr. 2000;23(4 Pt 1):450-56. Comparison: Psych. therapy vs. control. [pmid: 10793433].
6 Giorgberidze I, Saksena S, Krol RB, et al. Risk stratification and clinical outcome of minimally symptomatic and asymptomatic patients with nonsustained ventricular tachycardia and coronary disease: a prospective single-center study. Am J Cardiol. Sep. 11. 1997;80(5B):3F-9F. Comparison: ICD or drug 1 vs. drug 2. [pmid: 9291444].

## Not Intervention of Interest (n=3)

1 Rodriguez Y, Garisto JD, Carrillo RG. Laser lead extraction in the octogenarian patient. Circ Arrhythm Electrophysiol. Oct. 2011;4(5):719-23. Lead extraction. [pmid: 22007037].
2 Mela T, McGovern BA, Garan H, et al. Long-term infection rates associated with the pectoral versus abdominal approach to cardioverter- defibrillator implants. Am J Cardiol. Oct. 1. 2001;88(7):750-53. Abdominal implants. [pmid: 11589841].
3 Buxton AE, Lee KL, Fisher JD, et al. A randomized study of the prevention of sudden death in patients with coronary artery disease. Multicenter Unsustained Tachycardia Trial Investigators. N Engl J Med. Dec. 16. 1999;341(25):1882-90. Not an ICD trial. [pmid: 10601507].

## Outcome Numerator or Denominator Unclear (n=8)

1 Duggirala HJ, Herz ND, Canos DA, et al. Disproportionality analysis for signal detection of implantable cardioverter-defibrillator-related adverse events in the Food and Drug Administration Medical Device Reporting System. Pharmacoepidemiol Drug Saf. Jan. 2012;21(1):87-93. [pmid: 22095760].
2 Smith T, van Dessel PF, Theuns DA, et al. Health care utilisation after defibrillator implantation for primary prevention according to the guidelines in 2 Dutch academic medical centres. Neth Heart J. Oct. 2011;19(10):405-11. [pmid: 21773744].
3 Rodriguez Y, Baltodano P, Tower A, et al. Management of symptomatic inadvertently placed endocardial leads in the left ventricle. Pacing Clin Electrophysiol. Oct. 2011;34(10):1192-200. [pmid: 21671951].
4 van G I, Phan HM, Wilkoff BL, et al. Prognostic significance of atrial arrhythmias in a primary prevention ICD population. Pacing Clin Electrophysiol. Sep. 2011;34(9):1070-79. [pmid: 21605131].
5 Smit J, Korup E, Schonheyder HC. Infections associated with permanent pacemakers and implanted cardioverter-defibrillator devices. A 10-year regional study in Denmark. Scand J Infect Dis. Sep. 2010;42(9):658-64. [pmid: 20465488].
6 Santini M, Lunati M, Defaye P, et al. Prospective multicenter randomized trial of fast ventricular tachycardia termination by prolonged versus conventional anti-tachyarrhythmia burst pacing in implantable cardioverter-defibrillator patients-Atp DeliVery for pAiNless ICD thErapy (ADVANCE-D) Trial results. J Interv Card Electrophysiol. Mar. 2010;27(2):127-35. [pmid: 20087760].
7 Wilkoff BL, Williamson BD, Stern RS, et al. Strategic programming of detection and therapy parameters in implantable cardioverter-defibrillators reduces shocks in primary prevention patients: results from the PREPARE (Primary Prevention Parameters Evaluation) study. J Am Coll Cardiol. Aug. 12. 2008;52(7):541-50. [pmid: 18687248].
8 Wilkoff BL, Ousdigian KT, Sterns LD, et al. A comparison of empiric to physician-tailored programming of implantable cardioverter-defibrillators: results from the prospective randomized multicenter EMPIRIC trial. J Am Coll Cardiol. Jul. 18. 2006;48(2):330-39. [pmid: 16843184].

## Protocol (n=6)

1 Pedersen SS, Lambiase P, Boersma LV, et al. Evaluation oF FactORs ImpacTing CLinical Outcome and Cost EffectiveneSS of the S-ICD: design and rationale of the EFFORTLESS S-ICD Registry. Pacing Clin Electrophysiol. May. 2012;35(5):574-79. [pmid: 22360677].
2 Pedersen SS, Spek V, Theuns DA, et al. Rationale and design of WEBCARE: a randomized, controlled, web-based behavioral intervention trial in cardioverter-defibrillator patients to reduce anxiety and device concerns and enhance quality of life. Trials. 2009;10:120. [pmid: 20030843].
3 Moss AJ, Brown MW, Cannom DS, et al. Multicenter automatic defibrillator implantation trial-cardiac resynchronization therapy (MADIT-CRT): design and clinical protocol. Ann Noninvasive Electrocardiol. Oct. 2005;10(4 Suppl):34-43. [pmid: 16274414].
4 Moss AJ, et al. Multicenter automatic defibrillator implantation trial II (MADIT II): design and clinical protocol. Ann Noninvasive Electrocardiol. 2012.
5 Kadish A, Quigg R, Schaechter A, et al. Defibrillators in nonischemic cardiomyopathy treatment evaluation. Pacing Clin Electrophysiol. Mar. 2000;23(3):338-43. [pmid: 10750134].
6 Schuger C, Daubert JP, Brown MW, et al. Multicenter automatic defibrillator implantation trial: reduce inappropriate therapy (MADIT-RIT): background, rationale, and clinical protocol. Ann Noninvasive Electrocardiol. Jul. 2012;17(3):176-85. [pmid: 22816536].

## Review/Editorial (n=4)

1 Atwater BD, Daubert JP. Implantable cardioverter defibrillators: risks accompany the life-saving benefits. Heart. May. 2012;98(10):764-72. [pmid: 22422588].
2 Gasparini M, Nisam S. Implantable cardioverter defibrillator harm?. Europace. Aug. 2012;14(8):1087-93. [pmid: 22389417].
3 Kelly D, Mariathas M, Gough R, et al. Is a new high-voltage lead necessary? 6.6-French ICD lead failure: a UK tertiary center experience. Pacing Clin Electrophysiol. Jan. 2012;35(1):1-2. [pmid: 22077138].
4 Salukhe TV, Francis DP, Sutton R. Comparison of medical therapy, pacing and defibrillation in heart failure (COMPANION) trial terminated early; combined biventricular pacemaker-defibrillators reduce all-cause mortality and hospitalization. Int J Cardiol. Feb. 2003;87(2-3):119-20. [pmid: 12559527].

## Secondary Prevention (n=31)

1 Ye S, Grunnert M, Thune JJ, et al. Circumstances and outcomes of sudden unexpected death in patients with high-risk myocardial infarction: implications for prevention. Circulation. Jun. 14. 2011;123(23):2674-80. [pmid: 21606398].
2 Redhead AP, Turkington D, Rao S, et al. Psychopathology in postinfarction patients implanted with cardioverter-defibrillators for secondary prevention. A cross-sectional, case-controlled study. J Psychosom Res. Dec. 2010;69(6):555-63. [pmid: 21109043].
3 Hallas CN, Burke JL, White DG, et al. A prospective 1-year study of changes in neuropsychological functioning after implantable cardioverter-defibrillator surgery. Circ Arrhythm Electrophysiol. Apr. 2010;3(2):170-77. [pmid: 20197542].
4 MacFadden DR, Tu JV, Chong A, et al. Evaluating sex differences in population-based utilization of implantable cardioverter-defibrillators: role of cardiac conditions and noncardiac comorbidities. Heart Rhythm. Sep. 2009;6(9):1289-96. [pmid: 19695966].
5 Bagherzadeh A, Emkanjoo Z, Haghjoo M, et al. Complications and mortality of single versus dual chamber implantable cardioverter defibrillators. Indian Pacing Electrophysiol J. 2006;6(2):75-83. [pmid: 16943899].
6 Kron J. Clinical significance of device-related complications in clinical trials and implications for future trials: insights from the Antiarrhytmics Versus Implantable Defibrillators (AVID) trial. Card Electrophysiol Rev. Dec. 2003;7(4):473-78. [pmid: 15071278].
7 Kamphuis HC, de L Jr., Derksen R, et al. Implantable cardioverter defibrillator recipients: quality of life in recipients with and without ICD shock delivery: a prospective study. Europace. Oct. 2003;5(4):381-89. [pmid: 14753636].
8 Young JB, Abraham WT, Smith AL, et al. Combined cardiac resynchronization and implantable cardioversion defibrillation in advanced chronic heart failure: the MIRACLE ICD Trial. JAMA. May. 28. 2003;289(20):2685-94. [pmid: 12771115].
9 Fries R, Konig J, Schafers HJ, et al. Triggering effect of physical and mental stress on spontaneous ventricular tachyarrhythmias in patients with implantable cardioverter-defibrillators. Clin Cardiol. Oct. 2002;25(10):474-78. [pmid: 12375806].
10 Hsu J, Uratsu C, Truman A, et al. Life after a ventricular arrhythmia. Am Heart J. Sep. 2002;144(3):404-12. [pmid: 12228776].
11 Takahashi T, Bhandari AK, Watanuki M, et al. High incidence of device-related and lead-related complications in the dual-chamber implantable cardioverter defibrillator compared with the single-chamber version. Circ J. Aug. 2002;66(8):746-50. [pmid: 12197599].
12 Pires LA, Sethuraman B, Guduguntla VD, et al. Outcome of women versus men with ventricular tachyarrhythmias treated with the implantable cardioverter defibrillator. J Cardiovasc Electrophysiol. Jun. 2002;13(6):563-68. [pmid: 12108497].
13 Cook JR, Rizo-Patron C, Curtis AB, et al. Effect of surgical revascularization in patients with coronary artery disease and ventricular tachycardia or fibrillation in the Antiarrhythmics Versus Implantable Defibrillators (AVID) Registry. Am Heart J. May. 2002;143(5):821-26. [pmid: 12040343].
14 Della BP. Canadian Implantable Defibrillator Study (CIDS): a randomized trial of the implantable cardioverter defibrillator against amiodarone. Ital Heart J Suppl. Aug. 2000;1(8):1070-71. [pmid: 10993020].
15 Connolly SJ, Gent M, Roberts RS, et al. Canadian implantable defibrillator study (CIDS) : a randomized trial of the implantable cardioverter defibrillator against amiodarone. Circulation. Mar. 21. 2000;101(11):1297-302. [pmid: 10725290].
16 Dunbar SB, Kimble LP, Jenkins LS, et al. Association of mood disturbance and arrhythmia events in patients after cardioverter defibrillator implantation. Depress Anxiety. 1999;9(4):163-68. [pmid: 10431681].
17 Trappe HJ, Achtelik M, Pfitzner P, et al. Single-chamber versus dual-chamber implantable cardioverter defibrillators: indications and clinical results. Am J Cardiol. Mar. 11. 1999;83(5B):8D-16D. [pmid: 10089834].
18 Heller SS, Ormont MA, Lidagoster L, et al. Psychosocial outcome after ICD implantation: a current perspective. Pacing Clin Electrophysiol. Jun. 1998;21(6):1207-15. [pmid: 9633062].
19 Bourke JP, Turkington D, Thomas G, et al. Florid psychopathology in patients receiving shocks from implanted cardioverter-defibrillators. Heart. Dec. 1997;78(6):581-83. [pmid: 9470875].
20 Schuster PM, Phillips S, Dillon DL, et al. The psychosocial and physiological experiences of patients with an implantable cardioverter defibrillator. Rehabil Nurs. Jan. 1998;23(1):30-37. [pmid: 9460456].
21 Domanski MJ, Saksena S, Wyse G, et al. Clinical and socioeconomic profile of patients with malignant ventricular arrhythmias in 1993 to 1995. AVID investigators. Antiarrhythmics Versus Implantable Defibrillator. Am J Cardiol. Aug. 1. 1997;80(3):299-301. [pmid: 9264422].
22 Hegel MT, Griegel LE, Black C, et al. Anxiety and depression in patients receiving implanted cardioverter-defibrillators: a longitudinal investigation. Int J Psychiatry Med. 1997;27(1):57-69. [pmid: 9565714].
23 Haffajee C, Martin D, Bhandari A, et al. A multicenter, randomized trial comparing an active can implantable defibrillator with a passive can system. Jewel Active Can Investigators. Pacing Clin Electrophysiol. Jan. 1997;20(1 Pt 2):215-19. [pmid: 9121993].
24 Ector H, Jordaens L, Vanhaecke J. Survival analysis and clinical medicine. An observational comparison of the implantable cardioverter defibrillator, amiodarone treatment, and heart transplantation. Eur Heart J. Sep. 1996;17(9):1444-47. [pmid: 8880032].
25 Fleurant E, Lacroix D, Klug D, et al. Automatic implantable defibrillator and antiarrhythmic surgery in ischemic cardiopathies. Apropos of 53 cases. Arch Mal Coeur Vaiss. Nov. 1995;88(11):1627-34. [pmid: 8745998].
26 Arteaga WJ, Windle JR. The quality of life of patients with life-threatening arrhythmias. Arch Intern Med. Oct. 23. 1995;155(19):2086-91. [pmid: 7575068].
27 Clinical outcome of patients with malignant ventricular tachyarrhythmias and a multiprogrammable implantable cardioverter-defibrillator implanted with or without thoracotomy: an international multicenter study. PCD Investigator Group. J Am Coll Cardiol. Jun. 1994;23(7):1521-30. [pmid: 8195508].
28 Trappe HJ, Klein H, Wenzlaff P, et al. Role of interventional therapy in patients with coronary heart disease and life-threatening ventricular tachyarrhythmias. Eur Heart J. Sep. Suppl E. 1993;14:120-27. [pmid: 8223748].
29 Gross JN, Sackstein RD, Song SL, et al. The antitachycardia pacing ICD: impact on patient selection and outcome. Pacing Clin Electrophysiol. Jan. 1993;16(1 Pt 2):165-69. [pmid: 7681565].
30 Pinski SL, Mick MJ, Arnold AZ, et al. Retrospective analysis of patients undergoing one- or two-stage strategies for myocardial revascularization and implantable cardioverter defibrillator implantation. Pacing Clin Electrophysiol. Jul. 1991;14(7):1138-47. [pmid: 1715551].
31 Thomas AC, Moser SA, Smutka ML, et al. Implantable defibrillation: eight years clinical experience. Pacing Clin Electrophysiol. Nov. 1988;11(11 Pt 2):2053-58. [pmid: 2463587].

## Not Study Design of Interest (n=66)

1 Hickman RL Jr., Pinto MD, Lee E, et al. Exploratory and confirmatory factor analysis of the decision regret scale in recipients of internal cardioverter defibrillators. J Nurs Meas. 2012;20(1):21-34. Reason for Exclusion: cross-sectional. [pmid: 22679707].
2 van Rees JB, Borleffs CJ, van Welsenes GH, et al. Clinical prediction model for death prior to appropriate therapy in primary prevention implantable cardioverter defibrillator patients with ischaemic heart disease: the FADES risk score. Heart. Jun. 2012;98(11):872-77. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 22581736].
3 Carroll SL, Markle-Reid M, Ciliska D, et al. Age and mental health predict early device-specific quality of life in patients receiving prophylactic implantable defibrillators. Can J Cardiol. Jul. 2012;28(4):502-07. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 22425267].
4 Bruggenjurgen B, Israel CW, Klesius AA, et al. Health services research in heart failure patients treated with a remote monitoring device in Germany-a retrospective database analysis in evaluating resource use. J Med Econ. 2012;15(4):737-45. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 22409232].
5 Ziegler PD, Koehler JL, Verma A. Continuous versus intermittent monitoring of ventricular rate in patients with permanent atrial fibrillation. Pacing Clin Electrophysiol. May. 2012;35(5):598-604. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 22394432].
6 James CA, Tichnell C, Murray B, et al. General and disease-specific psychosocial adjustment in patients with arrhythmogenic right ventricular dysplasia/cardiomyopathy with implantable cardioverter defibrillators: a large cohort study. Circ Cardiovasc Genet. Feb. 1. 2012;5(1):18-24. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 22238189].
7 Epstein AJ, Polsky D, Yang F, et al. Geographic variation in implantable cardioverter-defibrillator use and heart failure survival. Med Care. Jan. 2012;50(1):10-17. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 22167063].
8 Scott PA, Whittaker A, Zeb M, et al. Rates of upgrade of ICD recipients to CRT in clinical practice and the potential impact of the more liberal use of CRT at initial implant. Pacing Clin Electrophysiol. Jan. 2012;35(1):73-80. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 22054072].
9 Cesarino CB, Beccaria LM, Aroni MM, et al. Quality of life of patients with implantable cardioverser-defibrillator: the usage of SF-36 questionnaire. Rev Bras Cir Cardiovasc. Apr. 2011;26(2):238-43. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 21894414].
10 Kramer DB, Friedman PA, Kallinen LM, et al. Development and validation of a risk score to predict early mortality in recipients of implantable cardioverter-defibrillators. Heart Rhythm. Jan. 2012;9(1):42-46. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 21893137].
11 Sack S, Wende CM, Nagele H, et al. Potential value of automated daily screening of cardiac resynchronization therapy defibrillator diagnostics for prediction of major cardiovascular events: results from Home-CARE (Home Monitoring in Cardiac Resynchronization Therapy) study. Eur J Heart Fail. Sep. 2011;13(9):1019-27. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 21852311].
12 Fischer A, Ousdigian KT, Johnson JW, et al. The impact of atrial fibrillation with rapid ventricular rates and device programming on shocks in 106,513 ICD and CRT-D patients. Heart Rhythm. Jan. 2012;9(1):24-31. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 21835150].
13 Lazarus A, Biondi N, Thebaut JF, et al. Implantable cardioverter-defibrillators in France: practices and regional variability. Europace. Nov. 2011;13(11):1568-73. Reason for Exclusion: cross-sectional. [pmid: 21784742].
14 Tavenaux M, Ginzburg DM, Boukacem A, et al. Changes in depression, anxiety, and vital exhaustion in patients after ICD implantation. Comparison of clinical subgroups. Herzschrittmacherther Elektrophysiol. Sep. 2011;22(3):174-79. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 21773789].
15 Pedersen SS, Versteeg H, Nielsen JC, et al. Patient-reported outcomes in Danish implantable cardioverter defibrillator patients with a Sprint Fidelis lead advisory notification. Europace. Sep. 2011;13(9):1292-98. Reason for Exclusion: cross-sectional. [pmid: 21616945].
16 Flemme I, Hallberg U, Johansson I, et al. Uncertainty is a major concern for patients with implantable cardioverter defibrillators. Heart Lung. Sep. 2011;40(5):420-28. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 21459446].
17 Probst V, Plassard-Kerdoncuf D, Mansourati J, et al. The psychological impact of implantable cardioverter defibrillator implantation on Brugada syndrome patients. Europace. Jul. 2011;13(7):1034-39. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 21427091].
18 Mellert F, Schneider C, Esmailzadeh B, et al. Implantation of left ventricular epicardial leads in cardiosurgical patients with impaired cardiac function--a worthwhile procedure in concomitant surgical interventions?. Thorac Cardiovasc Surg. Feb. 2012;60(1):64-69. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 21425053].
19 Alla VM, Anand K, Hundal M, et al. Impact of moderate to severe renal impairment on mortality and appropriate shocks in patients with implantable cardioverter defibrillators. Cardiol Res Pract. 2010;2010:150285. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 21197424].
20 Cross NJ, McCrae CS, Smith KM, et al. Comparison of actigraphic and subjective measures of sleep in implantable cardioverter defibrillator and coronary artery disease patients. Clin Cardiol. Dec. 2010;33(12):753-59. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 21184559].
21 Arnous S, Murphy NF, Pyne-Daly P, et al. Clinical and psychological impact of prophylactic implantable cardioverter-defibrillators in a community heart failure population. Ir J Med Sci. Jun. 2011;180(2):369-74. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 21153928].
22 Leistner DM, Schmitt J, Palm S, et al. Intracoronary administration of bone marrow-derived mononuclear cells and arrhythmic events in patients with chronic heart failure. Eur Heart J. Feb. 2011;32(4):485-91. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 21138937].
23 Bilchick KC, Kamath S, DiMarco JP, et al. Bundle-branch block morphology and other predictors of outcome after cardiac resynchronization therapy in Medicare patients. Circulation. Nov. 16. 2010;122(20):2022-30. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 21041691].
24 Hager CS, Jain S, Blackwell J, et al. Effect of renal function on survival after implantable cardioverter defibrillator placement. Am J Cardiol. Nov. 1. 2010;106(9):1297-300. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 21029827].
25 Versteeg H, Baumert J, Kolb C, et al. Somatosensory amplification mediates sex differences in psychological distress among cardioverter-defibrillator patients. Health Psychol. Sep. 2010;29(5):477-83. Reason for Exclusion: cross-sectional. [pmid: 20836602].
26 Chen TB, Cheng KA, Gao P, et al. Primary prevention of sudden cardiac death by implantable cardioverter-defibrillator therapy in Chinese patients with heart failure: a single-center experience. Chin Med J (Engl ). Apr. 5. 2010;123(7):848-51. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 20497676].
27 Marijon E, Trinquart L, Otmani A, et al. Predictors for short-term progressive heart failure death in New York Heart Association II patients implanted with a cardioverter defibrillator--the EVADEF study. Am Heart J. Apr. 2010;159(4):659-64. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 20362726].
28 Salukhe TV, Briceno NI, Ferenczi EA, et al. Is there benefit in implanting defibrillators in patients with severe heart failure?. Heart. Apr. 2010;96(8):599-603. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 20357388].
29 Desai H, Aronow WS, Ahn C, et al. Incidence of appropriate cardioverter-defibrillator shocks and mortality in patients with heart failure treated with combined cardiac resynchronization plus implantable cardioverter-defibrillator therapy versus implantable cardioverter-defibrillator therapy. J Cardiovasc Pharmacol Ther. Mar. 2010;15(1):37-40. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 19966176].
30 Borleffs CJ, van Welsenes GH, van Bommel RJ, et al. Mortality risk score in primary prevention implantable cardioverter defibrillator recipients with non-ischaemic or ischaemic heart disease. Eur Heart J. Mar. 2010;31(6):712-18. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 19933693].
31 Kim JS, Pressler SJ, Welch JL, et al. Physical function of patients with implantable cardioverter-defibrillators. J Cardiovasc Nurs. Sep. 2009;24(5):398-409. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 19707100].
32 Otmani A, Trinquart L, Marijon E, et al. Rates and predictors of appropriate implantable cardioverter-defibrillator therapy delivery: results from the EVADEF cohort study. Am Heart J. Aug. 2009;158(2):230-37. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 19619699].
33 Srivatsa UN, Hoppe BL, Narayan S, et al. Ventricular arrhythmia discriminator programming and the impact on the incidence of inappropriate therapy in patients with implantable cardiac defibrillators. Indian Pacing Electrophysiol J. 2007;7(2):77-84. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 17538699].
34 Baumert J, Schmitt C, Ladwig KH. Psychophysiologic and affective parameters associated with pain intensity of cardiac cardioverter defibrillator shock discharges. Psychosom Med. Jul. 2006;68(4):591-97. Reason for Exclusion: cross-sectional. [pmid: 16868269].
35 Klein T, Schonecke O, Wollny H, et al. Clinical significance of stress reactivity for frequency of electric shock discharges in patients with implanted cardioverter-defibrillators. Dtsch Med Wochenschr. Oct. 22. 2004;129(43):2291-94. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 15483767].
36 Godemann F, Butter C, Lampe F, et al. Panic disorders and agoraphobia: side effects of treatment with an implantable cardioverter/defibrillator. Clin Cardiol. Jun. 2004;27(6):321-26. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 15237689].
37 Ricci R, Quesada A, Pignalberi C, et al. Dual defibrillator improves quality of life and decreases hospitalizations in patients with drug refractory atrial fibrillation. J Interv Card Electrophysiol. Feb. 2004;10(1):85-92. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 14739755].
38 Hamilton GA, Carroll DL. The effects of age on quality of life in implantable cardioverter defibrillator recipients. J Clin Nurs. Feb. 2004;13(2):194-200. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 14723671].
39 Carroll DL, Hamilton GA, Kenney BJ. Changes in health status, psychological distress, and quality of life in implantable cardioverter defibrillator recipients between 6 months and 1 year after implantation. Eur J Cardiovasc Nurs. Oct. 2002;1(3):213-19. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 14622676].
40 Bolse K, Flemme I, Ivarsson A, et al. Life situation related to the ICD implantation; self-reported uncertainty and satisfaction in Swedish and US samples. Eur J Cardiovasc Nurs. Dec. 2002;1(4):243-51. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 14622654].
41 Pelletier D, Gallagher R, Mitten-Lewis S, et al. Australian implantable cardiac defibrillator recipients: quality-of-life issues. Int J Nurs Pract. Apr. 2002;8(2):68-74. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 11993579].
42 Flemme I, Bolse K, Ivarsson A, et al. Life situation of patients with an implantable cardioverter defibrillator: a descriptive longitudinal study. J Clin Nurs. Jul. 2001;10(4):563-72. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 11822504].
43 Wathen MS, Sweeney MO, DeGroot PJ, et al. Shock reduction using antitachycardia pacing for spontaneous rapid ventricular tachycardia in patients with coronary artery disease. Circulation. Aug. 14. 2001;104(7):796-801. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 11502705].
44 Ahmad M, Bloomstein L, Roelke M, et al. Patients' attitudes toward implanted defibrillator shocks. Pacing Clin Electrophysiol. Jun. 2000;23(6):934-38. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 10879375].
45 Pelletier D, Mitten-Lewis S, Gallagher RD, et al. Implantable defibrillator recipients' responses to device implantation and design. Biomed Instrum Technol. May. 1999;33(3):224-29. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 10360211].
46 Pauli P, Wiedemann G, Dengler W, et al. Anxiety in patients with an automatic implantable cardioverter defibrillator: what differentiates them from panic patients?. Psychosom Med. Jan. 1999;61(1):69-76. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 10024069].
47 Grubman EM, Pavri BB, Shipman T, et al. Cardiac death and stored electrograms in patients with third-generation implantable cardioverter-defibrillators. J Am Coll Cardiol. Oct. 1998;32(4):1056-62. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 9768732].
48 Crow SJ, Collins J, Justic M, et al. Psychopathology following cardioverter defibrillator implantation. Psychosomatics. Jul. 1998;39(4):305-10. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 9691699].
49 Craney JM, Mandle CL, Munro BH, et al. Implantable cardioverter defibrillators: physical and psychosocial outcomes. Am J Crit Care. Nov. 1997;6(6):445-51. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 9354222].
50 Jessurun ER, Hutten BA, van Hemel NM, et al. Good experiences with an implantable automatic defibrillator with transvenous electrodes for patients with life-threatening arrhythmias. Ned Tijdschr Geneeskd. Jul. 26. 1997;141(30):1475-80. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 9542881].
51 Herrmann C, von zur MF, Schaumann A, et al. Standardized assessment of psychological well-being and quality-of-life in patients with implanted defibrillators. Pacing Clin Electrophysiol. Jan. 1997;20(1 Pt 1):95-103. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 9121977].
52 Li H, Axtell K, Biehl M, et al. Sudden death in patients with implantable cardioverter-defibrillators. Am Heart J. Nov. 1996;132(5):986-88. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 8892772].
53 Jung W, Luderitz B. Quality of life and driving in recipients of the implantable cardioverter-defibrillator. Am J Cardiol. Sep. 12. 1996;78(5A):51-56. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 8820836].
54 Daoud EG, Strickberger SA, Man KC, et al. Comparison of early and late complications in patients undergoing coronary artery bypass graft surgery with and without concomitant placement of an implantable cardioverter defibrillator. Am Heart J. Oct. 1995;130(4):780-85. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 7572586].
55 Vitale MB, Funk M. Quality of life in younger persons with an implantable cardioverter defibrillator. Dimens Crit Care Nurs. Mar. 1995;14(2):100-11. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 7889798].
56 Bainger EM, Fernsler JI. Perceived quality of life before and after implantation of an internal cardioverter defibrillator. Am J Crit Care. Jan. 1995;4(1):36-43. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 7894553].
57 Luderitz B, Jung W, Deister A, et al. The quality of life after the implantation of a cardioverter/defibrillator in malignant arrhythmias. Dtsch Med Wochenschr. Mar. 5. 1993;118(9):285-89. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 8444109].
58 Nisam S, Mower MM, Thomas A, et al. Patient survival comparison in three generations of automatic implantable cardioverter defibrillators: review of 12 years, 25,000 patients. Pacing Clin Electrophysiol. Jan. 1993;16(1 Pt 2):174-78. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 7681567].
59 Pycha C, Calabrese JR, Gulledge AD, et al. Patient and spouse acceptance and adaptation to implantable cardioverter defibrillators. Cleve Clin J Med. Jul. 1990;57(5):441-44. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 2372924].
60 Boriani G, Botto G, Lunati M, et al. Influence of time between last myocardial infarction and prophylactic implantable defibrillator implant on device detections and therapies. “Routine Practice” data from the SEARCH MI registry. BMC Cardiovasc Disord. 2012;12:72. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 22966862].
61 Kreuz J, Horlbeck F, Schrickel J, et al. Kidney dysfunction and deterioration of ejection fraction pose independent risk factors for mortality in implantable cardioverter-defibrillator recipients for primary prevention. Clin Cardiol. Sep. 2012;35(9):575-79. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 22707222].
62 Parkash R, Sapp JL, Basta M, et al. Use of primary prevention implantable cardioverter-defibrillators in a population-based cohort is associated with a significant survival benefit. Circ Arrhythm Electrophysiol. Aug. 1. 2012;5(4):706-13. Reason for Exclusion: historic (not concurrent) control group. [pmid: 22685111].
63 van Rees JB, Borleffs CJ, van Welsenes GH, et al. Clinical prediction model for death prior to appropriate therapy in primary prevention implantable cardioverter defibrillator patients with ischaemic heart disease: the FADES risk score. Heart. Jun. 2012;98(11):872-77. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 22581736].
64 Thijssen J, van Rees JB, Venlet J, et al. The mode of death in implantable cardioverter-defibrillator and cardiac resynchronization therapy with defibrillator patients: results from routine clinical practice. Heart Rhythm. Oct. 2012;9(10):1605-12. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 22522066].
65 Carroll SL, Markle-Reid M, Ciliska D, et al. Age and mental health predict early device-specific quality of life in patients receiving prophylactic implantable defibrillators. Can J Cardiol. Jul. 2012;28(4):502-07. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 22425267].
66 Biasucci LM, Bellocci F, Landolina M, et al. Risk stratification of ischaemic patients with implantable cardioverter defibrillators by C-reactive protein and a multi-markers strategy: results of the CAMI-GUIDE study. Eur Heart J. Jun. 2012;33(11):1344-50. Reason for Exclusion: Cohort study, no adverse events or N<500. [pmid: 22285581].

## Wrong Population (n=37)

1 Viola GM, Awan LL, Ostrosky-Zeichner L, et al. Infections of cardiac implantable electronic devices: a retrospective multicenter observational study. Medicine (Baltimore). May. 2012;91(3):123-30. [pmid: 22543626].
2 Athan E, Chu VH, Tattevin P, et al. Clinical characteristics and outcome of infective endocarditis involving implantable cardiac devices. JAMA. Apr. 25. 2012;307(16):1727-35. [pmid: 22535857].
3 Deharo JC, Quatre A, Mancini J, et al. Long-term outcomes following infection of cardiac implantable electronic devices: a prospective matched cohort study. Heart. May. 2012;98(9):724-31. [pmid: 22523057].
4 Powell BD, Asirvatham SJ, Perschbacher DL, et al. Noise, artifact, and oversensing related inappropriate ICD shock evaluation: ALTITUDE noise study. Pacing Clin Electrophysiol. Jul. 2012;35(7):863-69. [pmid: 22519674].
5 Viganego F, O'Donoghue S, Eldadah Z, et al. Effect of early diagnosis and treatment with percutaneous lead extraction on survival in patients with cardiac device infections. Am J Cardiol. May. 15. 2012;109(10):1466-71. [pmid: 22356796].
6 Greenspon AJ, Prutkin JM, Sohail MR, et al. Timing of the most recent device procedure influences the clinical outcome of lead-associated endocarditis results of the MEDIC (Multicenter Electrophysiologic Device Infection Cohort). J Am Coll Cardiol. Feb. 14. 2012;59(7):681-87. [pmid: 22322085].
7 Jacob S, Panaich SS, Zalawadiya SK, et al. Phantom shocks unmasked: clinical data and proposed mechanism of memory reactivation of past traumatic shocks in patients with implantable cardioverter defibrillators. J Interv Card Electrophysiol. Aug. 2012;34(2):205-13. [pmid: 22183617].
8 Bogale N, Priori S, Cleland JG, et al. The European CRT Survey: 1 year (9-15 months) follow-up results. Eur J Heart Fail. Jan. 2012;14(1):61-73. [pmid: 22179034].
9 Bogale N, Witte K, Priori S, et al. The European Cardiac Resynchronization Therapy Survey: comparison of outcomes between de novo cardiac resynchronization therapy implantations and upgrades. Eur J Heart Fail. Sep. 2011;13(9):974-83. [pmid: 21771823].
10 Le KY, Sohail MR, Friedman PA, et al. Impact of timing of device removal on mortality in patients with cardiovascular implantable electronic device infections. Heart Rhythm. Nov. 2011;8(11):1678-85. [pmid: 21699855].
11 Tompkins C, McLean R, Cheng A, et al. End-stage renal disease predicts complications in pacemaker and ICD implants. J Cardiovasc Electrophysiol. Oct. 2011;22(10):1099-104. [pmid: 21489029].
12 Powell BD, Cha YM, Asirvatham SJ, et al. Implantable cardioverter defibrillator electrogram adjudication for device registries: methodology and observations from ALTITUDE. Pacing Clin Electrophysiol. Aug. 2011;34(8):1003-12. [pmid: 21453341].
13 Sohail MR, Hussain S, Le KY, et al. Risk factors associated with early- versus late-onset implantable cardioverter-defibrillator infections. J Interv Card Electrophysiol. Aug. 2011;31(2):171-83. [pmid: 21365264].
14 Krahn AD, Lee DS, Birnie D, et al. Predictors of short-term complications after implantable cardioverter-defibrillator replacement: results from the Ontario ICD Database. Circ Arrhythm Electrophysiol. Apr. 2011;4(2):136-42. [pmid: 21325209].
15 Cengiz M, Okutucu S, Ascioglu S, et al. Permanent pacemaker and implantable cardioverter defibrillator infections: seven years of diagnostic and therapeutic experience of a single center. Clin Cardiol. Jul. 2010;33(7):406-11. [pmid: 20641117].
16 Tompkins C, Cheng A, Dalal D, et al. Dual antiplatelet therapy and heparin “bridging” significantly increase the risk of bleeding complications after pacemaker or implantable cardioverter-defibrillator device implantation. J Am Coll Cardiol. May. 25. 2010;55(21):2376-82. [pmid: 20488310].
17 Nery PB, Fernandes R, Nair GM, et al. Device-related infection among patients with pacemakers and implantable defibrillators: incidence, risk factors, and consequences. J Cardiovasc Electrophysiol. Jul. 2010;21(7):786-90. [pmid: 20102431].
18 de Oliveira JC, Martinelli M, Nishioka SA, et al. Efficacy of antibiotic prophylaxis before the implantation of pacemakers and cardioverter-defibrillators: results of a large, prospective, randomized, double-blinded, placebo-controlled trial. Circ Arrhythm Electrophysiol. Feb. 2009;2(1):29-34. [pmid: 19808441].
19 Curtis LH, Al-Khatib SM, Shea AM, et al. Sex differences in the use of implantable cardioverter-defibrillators for primary and secondary prevention of sudden cardiac death. JAMA. Oct. 3. 2007;298(13):1517-24. [pmid: 17911496].
20 Gunderson BD, Patel AS, Bounds CA, et al. An algorithm to predict implantable cardioverter-defibrillator lead failure. J Am Coll Cardiol. Nov. 2. 2004;44(9):1898-902. [pmid: 15519026].
21 Cabell CH, Heidenreich PA, Chu VH, et al. Increasing rates of cardiac device infections among Medicare beneficiaries: 1990-1999. Am Heart J. Apr. 2004;147(4):582-86. [pmid: 15077071].
22 Giudici MC, Paul DL, Bontu P, et al. Pacemaker and implantable cardioverter defibrillator implantation without reversal of warfarin therapy. Pacing Clin Electrophysiol. Mar. 2004;27(3):358-60. [pmid: 15009863].
23 Newman DM, Dorian P, Paquette M, et al. Effect of an implantable cardioverter defibrillator with atrial detection and shock therapies on patient-perceived, health-related quality of life. Am Heart J. May. 2003;145(5):841-46. [pmid: 12766741].
24 Gronefeld GC, Mauss O, Li YG, et al. Association between atrial fibrillation and appropriate implantable cardioverter defibrillator therapy: results from a prospective study. J Cardiovasc Electrophysiol. Nov. 2000;11(11):1208-14. [pmid: 11083241].
25 Hua W, Niu H, Fan X, et al. Preventive effectiveness of implantable cardioverter defibrillator in reducing sudden cardiac death in the Chinese population: a multicenter trial of ICD therapy versus non-ICD therapy. J Cardiovasc Electrophysiol. Nov. Suppl 1. 2012;23:S5-S9. [pmid: 23140347].
26 Dougherty CM, Thompson EA, Kudenchuk PJ. Development and testing of an intervention to improve outcomes for partners following receipt of an implantable cardioverter defibrillator in the patient. ANS Adv Nurs Sci. Oct. 2012;35(4):359-77. [pmid: 23107992].
27 Chen S, Yin Y, Krucoff MW. Effect of cardiac resynchronization therapy and implantable cardioverter defibrillator on quality of life in patients with heart failure: a meta-analysis. Europace. Nov. 2012;14(11):1602-07. [pmid: 23104857].
28 Rho RW, Patton KK, Poole JE, et al. Important differences in mode of death between men and women with heart failure who would qualify for a primary prevention implantable cardioverter-defibrillator. Circulation. Nov. 13. 2012;126(20):2402-07. [pmid: 23072904].
29 Healey JS, Hohnloser SH, Exner DV, et al. Cardiac resynchronization therapy in patients with permanent atrial fibrillation: results from the Resynchronization for Ambulatory Heart Failure Trial (RAFT). Circ Heart Fail. Sep. 1. 2012;5(5):566-70. [pmid: 22896584].
30 Ipek EG, Guray U, Demirkan B, et al. Infections of implantable cardiac rhythm devices: predisposing factors and outcome. Acta Cardiol. Jun. 2012;67(3):303-10. [pmid: 22870738].
31 Brignole M, Occhetta E, Bongiorni MG, et al. Clinical evaluation of defibrillation testing in an unselected population of 2,120 consecutive patients undergoing first implantable cardioverter-defibrillator implant. J Am Coll Cardiol. Sep. 11. 2012;60(11):981-87. [pmid: 22858384].
32 Roig IL, Darouiche RO, Musher DM, et al. Device-related infective endocarditis, with special consideration of implanted intravascular and cardiac devices in a predominantly male population. Scand J Infect Dis. Oct. 2012;44(10):753-60. [pmid: 22681242].
33 Hoogwegt MT, Kupper N, Theuns DA, et al. Undertreatment of anxiety and depression in patients with an implantable cardioverter-defibrillator: impact on health status. Health Psychol. Nov. 2012;31(6):745-53. [pmid: 22545981].
34 Powell BD, Asirvatham SJ, Perschbacher DL, et al. Noise, artifact, and oversensing related inappropriate ICD shock evaluation: ALTITUDE noise study. Pacing Clin Electrophysiol. Jul. 2012;35(7):863-69. [pmid: 22519674].
35 Boriani G, Santini M, Lunati M, et al. Improving thromboprophylaxis using atrial fibrillation diagnostic capabilities in implantable cardioverter-defibrillators: the multicentre Italian ANGELS of AF Project. Circ Cardiovasc Qual Outcomes. Mar. 1. 2012;5(2):182-88. [pmid: 22373906].
36 Koopman HM, Vrijmoet-Wiersma CM, Langius JN, et al. Psychological functioning and disease-related quality of life in pediatric patients with an implantable cardioverter defibrillator. Pediatr Cardiol. Apr. 2012;33(4):569-75. [pmid: 22314365].
37 Marshall P, Ketchell A, Maclean J. Comparison of male and female psychological outcomes related to implantable cardioverter defibrillators (COMFORTID). Eur J Cardiovasc Nurs. Sep. 2012;11(3):313-21. [pmid: 21802370].

## Other (n=4)

1 Sayfo S, Vakil KP, Alqaqa'a A, et al. A retrospective analysis of proceduralist-directed, nurse-administered propofol sedation for implantable cardioverter-defibrillator procedures. Heart Rhythm. Mar. 2012;9(3):342-46. Reason for Exclusion: inpatient adverse effect, not NCDR ICD database. [pmid: 22001710].
2 Swindle JP, Rich MW, McCann P, et al. Implantable cardiac device procedures in older patients: use and in-hospital outcomes. Arch Intern Med. Apr. 12. 2010;170(7):631-37. Reason for Exclusion: Inpatient adverse effect, not NCDR ICD database. [pmid: 20386008].
3 Bhavnani SP, Kluger J, Coleman CI, et al. The prognostic impact of shocks for clinical and induced arrhythmias on morbidity and mortality among patients with implantable cardioverter-defibrillators. Heart Rhythm. Jun. 2010;7(6):755-60. Reason for Exclusion: No data about population. [pmid: 20211275].
4 Zaman S, Sivagangabalan G, Narayan A, et al. Outcomes of early risk stratification and targeted implantable cardioverter-defibrillator implantation after ST-elevation myocardial infarction treated with primary percutaneous coronary intervention. Circulation. Jul. 21. 2009;120(3):194-200. Reason for Exclusion: intervention arms not comparable. [pmid: 19581496].