# Search Strategy

Databases
1. Ovid MEDLINE ^®^ 1948 to December Week 1 2012
2. Ovid MEDLINE ^®^ In-Process & Other Non-Indexed Citations November 30, 2012
3. EBM Reviews-Cochrane Central Register of Controlled Trials 4^th^ Quarter 2012

Search Terms

# | Searches | Brief description of terms | Number of abstracts
1 | defibrillators, implantable.sh. | Terms related to device of interest | 9,770
2 | (defibrillators and implantable).af. | Terms related to device of interest | 10,520
3 | implantable defibrillators.af. | Terms related to device of interest | 656
4 | (implantable and cardioverter and defibrillator).af. | Terms related to device of interest | 5,507
5 | implantable cardioverter defibrillator.af. | Terms related to device of interest | 4,645
6 | cardioverter defibrillators, implantable.af. | Terms related to device of interest | 1
7 | (death, sudden, cardiac and cardiac pacing, artificial).af. | Terms related to outcome of interest | 310
8 | or/1-7 | | 11,828
9 | randomized controlled trial.pt. | RCT module | 623,823
10 | controlled clinical trial.pt | RCT module | 164,766
11 | randomized controlled trials/ | RCT module | 83,169
12 | Random Allocation/ | RCT module | 93,931
13 | Double-blind Method/ | RCT module | 208,115
14 | Single-Blind Method/ | RCT module | 25,802
15 | clinical trial.pt. | RCT module | 745,680
16 | Clinical Trials.mp. or exp Clinical Trials/ | RCT module | 304,982
17 | (clinic$ adj25 trial$).tw. | RCT module | 270,192
18 | ((singl$ or doubl$ or trebl$ or tripl$) adj (mask$ or blind$)).tw. | RCT module | 238,018
19 | Placebos/ | RCT module | 50,936
20 | placebo$.tw. | RCT module | 253,666
21 | random$.tw. | RCT module | 877,789
22 | trial$.tw. | RCT module | 687,536
23 | (randomized control trial or clinical control trial).sd. | RCT module | 232,482
24 | (latin adj square).tw. | RCT module | 3,834
25 | Comparative Study.tw. or Comparative Study.pt. | RCT module | 1,718,659
26 | exp Evaluation studies/ | RCT module | 160,402
27 | Follow-Up Studies/ | RCT module | 472,156
28 | Prospective Studies/ | RCT module | 367,536
29 | (control$ or prospectiv$ or volunteer$).tw. | RCT module | 2,861,505
30 | Cross-Over Studies/ | RCT module | 51,220
31 | or/9-30 | RCT module | 5,503,700
32 | 8 and 31 | Comparative ICD studies | 5,457
33 | exp cohort studies/ or exp prospective studies/ or exp retrospective studies/ or exp epidemiologic studies/ or exp case-control studies/ | Cohort module | 1,471,173
34 | (cohort or retrospective or prospective or longitudinal or observational or follow-up or followup or registry).af. | Cohort module | 1,819,849
35 | case-control.af. or (case adj10 control).tw. | Cohort module | 175,858
36 | ep.fs. (epidemiology/floating subhead) | Cohort module | 1,046,431
37 | or/33-36 | Cohort module | 2,709,357
38 | 8 not 31 | | 6,437
39 | 37 and 38 | Cohort ICD studies | 1,309
40 | 32 or 39 | All ICD studies | 6,766

NOTE: The above search strategy was successfully tested against the major RCTs identified in the review by Passman R, Kadish A. Sudden death prevention with implantable devices. Circulation. 2007;116:561-71. [pmid: 17664385]. .