# Acronyms

ADRIA: A+ versus DR Clinical Investigation of Arrhythmia Discrimination
AHRQ: Agency for Healthcare Research and Quality
AMIOVERT: Amiodarone Versus Implantable Cardioverter-Defibrillator: Randomized Trial in Patients With Nonischemic Dilated Cardiomyopathy and Asymptomatic Nonsustained Ventricular Tachycardia [trial]
AVID: Antiarrhythmics Versus Implantable Defibrillators [trial]
ATP: antitachycardia pacing
CABG: coronary artery bypass grafting
CABG-Patch: Coronary Artery Bypass Graft Patch [trial]
CAD: coronary artery disease
CAMIAT: Canadian Amiodarone Myocardial Infarction Arrhythmia Trial
CASH: Cardiac Arrest Study Hamburg
CAST: Cardiac Arrhythmia Suppression Trial
CAT: Cardiomyopathy Trial
CI: Confidence interval
CIDS: Canadian Implantable Defibrillator Study
CMS: Centers for Medicare and Medicaid Services
COMPANION: Comparison of Medical Therapy, Pacing and Defibrillation in Heart Failure [study]
CRT: cardiac resynchronization therapy
CRP-D: CRT with a biventricular defibrillator
CRT-P: CRT with a biventricular pacemaker (without a defibrillator)
DEFINITE: Defibrillators in Nonischemic Cardiomyopathy Treatment Evaluation
DINAMIT: Defibrillator in Acute Myocardial Infarction Trial
ECG: Electrocardiograms
EMIAT: European Myocardial Infarction Amiodarone Trial
ESRD: End stage renal disease
EPC: Evidence-based Practice Center
GWTG-HF: Get With the Guidelines-Heart Failure [study]
HR: hazard ratio
ICD: implantable cardioverter–defibrillator
IRIS: Immediate Risk Stratification Improves Survival [trial]
ITT: Intention-to-Treat
LV: left ventricular
LVEF: left ventricular ejection fraction
MADIT: Multicenter Automatic Defibrillator Implantation Trial
MADIT II: Multicenter Automatic Defibrillator Implantation Trial II
MADIT-CRT: Multicenter Automatic Defibrillator Implantation Trial with Cardiac Resynchronization Therapy
MENDMI: Prevention of Myocardial Enlargement and Dilation Post Myocardial Infarction [study]
MI: myocardial infarction
ms: millisecond(s)
NCDR: National Cardiovascular Data Registry
NNT: Number needed to treat
nRCS: nonrandomized comparative study
NYHA: New York Heart Association
OPTIMIZE-HF: Organized Program to Initiate Lifesaving Treatment in Hospitalized Patients with Heart Failure [study]
OR: odds ratio
QoL: quality of life
PCI: Percutaneous coronary intervention
RAFT: Resynchronization-Defibrillation for Ambulatory Heart Failure Trial
RCT: randomized controlled trial
RR: risk ratio
SA ECG: Signal Averaged ECG
SCD: sudden cardiac death
SCD-HeFT: Sudden Cardiac Death in Heart Failure Trial
SRDR: Systematic Review Data Repository
TOO: Task Order Officer
VF: ventricular fibrillation
VT: ventricular tachycardia