# Results

The literature search identified 7,571 abstracts. The abstract screening process identified a total of 375 full-text articles that were evaluated against the inclusion criteria. Of these, 60 studies published in 68 articles met the eligibility criteria (Appendix C, Figure 1).

## Key Question 1 (Long-term outcomes)

In asymptomatic patients with carotid artery stenosis, what is the evidence on long-term clinical outcomes (at least 12 months) including stroke, death, myocardial infarction, and other cardiovascular events for the following interventions and comparisons?

### Medical therapy alone (Key Question 1a)

A total of 41 studies assessed medical therapy and met our inclusion criteria (nine quality-A, 14 quality-B, and 18 quality-C studies). We evaluated the evidence on the absolute risk of long-term adverse clinical outcomes in patients with asymptomatic carotid stenosis and receiving medical therapy only (no revascularization procedure in the carotid artery of interest). We used the data from eligible single-arm prospective cohort studies of medical therapy, from the medical therapy groups of eligible RCTs and nonrandomized comparative studies and also followup data for the asymptomatic arteries of patients that underwent CEA to the contralateral carotid artery.

### Study characteristics

#### Eligibility criteria and diagnosis of asymptomatic carotid stenosis

The eligible studies included six RCTs comparing CEA with medical therapy, which reported results from the medical therapy group in eight publications.28-34,59 Among the six RCTs, there were three studies that provided data from the medical therapy group of the RCT,28,28,30-32 one study that provided data from the medical therapy group as well as additional data from the medical therapy group of the nonrandomized comparison of CEA and medical therapy59, one study that provided data from the medical therapy group as well as from the contralateral artery in the CEA group,29 a study of symptomatic patients that provided data from the asymptomatic contralateral artery of the CEA group, and the asymptomatic contralateral artery of the medical therapy group.33,34 We also included a nonrandomized comparative study of CEA and medical therapy that provided data from the medical therapy group.60 Additional data on medical therapy was obtained from a report on the events in the contralateral artery territory from two RCTs that compared CEA with primary closure and CEA with patching.37 The remaining studies included 33 single-arm prospective cohort studies. One study reported data for two different cohorts, which contributed to two separate meta-analytic strata.55

DUS was used to assess the degree of carotid stenosis in 31 studies (75.5 percent) and a combination of DUS and DSA was used to assess stenosis in seven studies (17 percent).32,38,42,59-62 DSA alone was used in two studies (5 percent) to assess carotid stenosis, 29,33,34 and one study did not provide information on the imaging modality used.43 The characteristics of included studies that reported data on ipsilateral stroke are provided in Table 1.

Table 1 Summary characteristics of studies of medical therapy that reported ipsilateral stroke

Study, Year, Country | Population | N subjects (followup yr) | Percent carotid stenosis | Contralateral status | Long-term outcomes
RCT^*^
ACAS, 1995 USA28 | Medical therapy group | 834 (5.25) | 60-99% DUS | 9% occlusion; 19% CEA | Stroke, death, ipsilateral TIA
ECST, 1995 Europe29 | Medical therapy group; contralateral to CEA | 127 (3.5) | 70-99% DSA | 100% CEA in surgical group | Only ipsilateral stroke
Halliday, 2004, 2010 (ACST) Europe30,31 | Medical therapy group | 1560 (4.4) | 60-99% DUS | 9% occlusion, 24% CEA | Stroke, death
Hobson, 1993 (VA) USA32 | Medical therapy group | 233 (9) | 50-99% DUS; DSA | 33% occlusion | Stroke, death, ipsilateral TIA
Inzitari, Anderson, 2000, 2002 USA33,34 | Contralateral asymptomatic artery in both groups | 324 (2.4) | 50-99% DSA | 100% CEA in surgical group | Fatal stroke, death, ipsilateral TIA
AbuRahma, 2003 USA^**,35^ | Contralateral asymptomatic artery to CEA | 101 (3.4) | 50-99% DUS | 100% CEA | Ipsilateral stroke and TIA
Prospective studies
Abbott, 2005 Australia36 | Medical Cohort | 202 (3) | 60-99% DUS | 5 % occlusion | Stroke, MI, ipsilateral TIA, non stroke death
AbuRahma, 2003 USA37 | Medical Cohort | 82 (5) | 60-69% DUS | 100 % occlusion | Stroke, death, ipsilateral TIA
Ballotta, 2007 Italy38 | Medical Cohort | 98 (2.7) | 50-69% DUS / DSA | 100% CEA | Ipsilateral stroke and TIA
Bogousslavsky, 1986 Switzerland39 | Medical Cohort | 38 (4.1) | 90-99% DUS | 0 % occlusion | Death, ipsilateral TIA
Goessens, 2007 The Netherlands40 | Medical Cohort | 221 (4.5) | 50-99% DUS | nd | Stroke, MI, death
Gronholdt, 2001 Denmark41 | Medical Cohort | 111 (4) | 50-99% DUS | nd | Death, ipsilateral TIA
Gur, 1996 Israel42 | Medical Cohort | 44 (3.6) | 70-99% DUS / DSA | nd | Ipsilateral stroke and TIA
Johnson, 1985 USA43 | Medical Cohort | 121 (4) | 75-99%; nd | nd | Ipsilateral stroke and TIA
Johnson, 1995 USA44 | Medical Cohort | 94 (2.9) | 50-79% DUS | nd | Only ipsilateral stroke
Levien, 1984 South Africa45 | Medical Cohort | 50 (3) | 50-99% DUS | nd | Ipsilateral stroke and TIA
Liapis, 2001 Greece46 | Medical Cohort | 136 (1.8) | 50-99% DUS | nd | Ipsilateral stroke and TIA
Mackey, 1997 Canada46,47 | Medical Cohort | 357 (3.7) | 50-99% DUS | nd | Stroke, ipsilateral TIA
Mansour, 1999 USA48 | Medical Cohort | 344 (5) | 50-79% DUS | nd | Stroke, death; ipsilateral TIA
Markus, 2010 International49 | Medical Cohort | 467 (3.1) | 70-99% DUS | nd^***^ | Stroke, ipsilateral TIA
Marquardt, 2010 UK50 | Medical Cohort | 101 (2.1) | 50-99% DUS | nd | Stroke, MI, ipsilateral TIA, death
Nicolaides, Kakkos, 2005 UK51,52 | Medical Cohort | 805 (3) | 50-99% DUS | nd | Death, ipsilateral TIA
Silvestrini, 2000 Italy53 | Medical Cohort | 94 (2) | 70-90% DUS | 0 % occlusion | Stroke, MI, ipsilateral TIA
Spence, 2005, 2010 Canada54,55 | Medical Cohort | 468 (1.4) | 60-99% DUS | nd | Stroke, MI, death
Takaya, 2006 USA56 | Medical Cohort | 154 (2) | 50-79% DUS | nd | Ipsilateral stroke and TIA
Longstreth, 1998 USA57 | Medical Cohort | 184 (1.5) | 50-99% DUS | 0 % occlusion | Stroke, ipsilateral TIA
Zhang, 2009 China58 | Medical Cohort | 62 (1) | 50-99% DUS | nd | Ipsilateral stroke and TIA, MI, death

DSA = digital subtraction angiography, DUS = duplex ultrasonography, MI = myocardial infarction, N= total number of patients analyzed, TIA = transient ischemic attack, nd = not documented

* All are RCTs of CEA versus medical therapy;

** Included two trials of CEA;

*** Included patients who had undergone CEA for the contralateral artery, but their proportion was unknown

#### Population

The studies included were conducted from 1978 through 2009. A total of 16,178 patients in 41 studies were followed for an average period of 3.4 years. The sample size of the studies ranged from 38 to 3,164, and the followup period ranged from 1 to 9 years. The average age of the participants across all studies was 68 years and ranged from 55 to 81 years. The proportion of octogenarians among the study populations ranged from zero to 40 percent, as reported in seven studies.28,30,31,33,34,39,41,50,59 The proportion of males in each study ranged from 40 to100 percent, with a median of 63.5 percent (Interquartile range: 57.3 to 74 percent).

The majority of the studies (22 of 41 studies, 54 percent) included participants who had never previously undergone a CEA in the contralateral carotid artery; of those, one study included patients with contralateral carotid occlusion.37 In 10 other studies (25 percent), a certain proportion of the included patients had undergone CEA in the contralateral carotid artery, ranging from 19 to 100 percent.28-31,33-35,38,49,60,63,64 In 9 studies (22 percent), it was not specified whether patients that had undergone CEA in the contralateral carotid artery were excluded from the study population.

The proportion of participants with hypertension ranged from 12 to 90 percent and the proportion of participants with coronary artery disease ranged from 14 to 81 percent. The range of prevalence of peripheral vascular disease was from 15 to 71 percent, and prevalence of hyperlipidemia was 5 to 79 percent. The proportion of participants who currently smoked or had ever smoked ranged from 14 to 91 percent.

#### Description of medical therapy

Of all 41 studies, 29 (71 percent) had information on the medical treatment being given to the participants, and among them, 28 (68 percent) reported details of the anti-thrombotic treatment given to the participants, and only 13 (32 percent) reported details of lipid-lowering treatment. Among these studies reporting data on the actual medical therapy received, the use of anti-thrombotic medication (including both anti-platelet as well as anti-coagulant drugs) ranged from 0 to 100 percent with the median of the proportion of patients using anti-thrombotic drugs being 91.5 percent of the participants. Similarly, the range of usage of lipid-lowering medications such as statins was from 5 to 88 percent, with the median of the proportion of patients using statins and other lipid-lowering drugs being 62 percent. Two studies disallowed the participants from taking any anti-platelet drugs.43,65 The details of the baseline characteristics are summarized in the Appendix E, Tables 1–2.

Incidence rates for cerebrovascular, mortality, and cardiovascular outcomes were calculated from 41 studies. Syntheses of these incidence rates were performed for outcomes of interest; results of these meta-analyses are shown below in Table 2.

Table 2 Meta-analyses of incidence rates of events for all medical therapy studies

Outcome | N of studies | Summary incidence rate (95% CI) | Median number of events (IQR) | Median person-years of followup (IQR)
Ipsilateral stroke | 26 | 0.0168 (0.0133 to 0.0211) | 10 (3 - 15) | 489.3 (337 – 851.9)
Ipsilateral stroke or TIA | 20 | 0.0550 (0.0437 to 0.0690) | 22 (8.5 – 49.5) | 398.4 (109.15 – 889)
Ipsilateral TIA | 9 | 0.0296 (0.0202 to 0.0435) | 8 (5 - 14) | 354.1 (223.3 – 406.6)
Any stroke | 17 | 0.0267 (0.0195, 0.0366) | 16 (7 - 27) | 713.8 (386.65 - 930)
Any stroke or TIA | 9 | 0.0557 (0.0398, 0.0781) | 23 (16 - 64) | 621.7 (223.25 -1106.7)
Any TIA | 5 | 0.0396 (0.0308, 0.0507) | 7 (4 - 8) | 108.5 (108.2 - 175)
Cardiovascular death | 6 | 0.0409 (0.0323, 0.0518) | 40 (23 - 91) | 1069.2 (301 - 2269.2)
Death | 14 | 0.0458 (0.0342 to 0.0613) | 55 (14 - 103) | 754.7 (406.6 - 2251.8)
MI | 5 | 0.0234 (0.0124, 0.0440) | 14 (2 - 14) | 398 (301 - 538)

CI = confidence interval, IQR = interquartile range, MI = myocardial infarction, TIA = transient ischemic attack.

#### Ipsilateral Stroke

The meta-analysis for ipsilateral stroke included 26 studies.28-35,37-58 Ipsilateral stroke occurrence was 1.68 events per 100 person-years of followup with medical therapy alone or 1.68 percent per year (summary incidence rate = 0.017, 95% CI = 0.013, 0.021) (Figure 1). The median number of ipsilateral stroke occurring in each study was small (n=10).

Figure 1 Forest plot of the incidence rates of ipsilateral stroke in medical therapy alone

The studies are ordered by the last year of recruitment in each study. Year of publication is provided in parentheses.

Figure 1 is a forest plot that depicts the incidence rates of ipsilateral stroke from medical therapy alone as assessed in 25 studies listed in Table 2. Along the left hand column, each study is listed in chronological order of recruitment closure year with each study's year of publication. The right hand column presents the incidence rate of ipsilateral stroke of each study. Overall ipsilateral stroke occurrence was 1.70 events per 100 person-years of followup with medical therapy alone or 1.70 percent per year (summary incidence rate = 0.0168, 95% CI = 0.013, 0.021).

#### Ipsilateral stroke or TIA

The summary estimate of 20 studies28,32-35,37,38,42,43,45-52,56,58,62,63,66 reporting the combined outcome of ipsilateral stroke or TIA was 5.5 percent per year (Appendix D, Figure 1).

#### Any stroke

The summary incidence rates for any stroke in 17 studies 28,31,32,37,40,47-49,53,55,57,59,60,67-69 and any stroke or TIA in nine studies47,48,53,64,67-71) were 2.7 and 5.6 percent per year, respectively (Appendix D, Figures 2 and 3).

#### Mortality

The meta-analysis of all-cause death included 14 studies.28,31,32,37,39-41,48,51,52,54,55,68,72,58 The summary incidence rate of all-cause death was 4.6 percent per year (Appendix D, Figure 4). Patients with medical therapy alone had 4.1 percent per year cardiovascular deaths in a meta-analysis of six studies.39,40,50-52,68,72

#### Composite cardiovascular outcomes

The analysis of composite outcomes included 15 studies.33,34,36,37,40,41,47,49,50,57,59,61,65,68,71,72 Studies used various combinations of acute coronary syndrome, ischemic cerebrovascular events, referral to revascularization, and cardiovascular or all-cause death to report the composite endpoint. The clinical heterogeneity of the reported outcomes precluded any meaningful synthesis of incidence rates of events across these studies. Five studies that reported separate data for the outcome of MI were subjected to meta-analysis; the summary incidence rate was 2.3 percent per year.40,50,53-55

#### Meta-regression and subgroup analyses

To examine the impact of time on the incidence rates of events, we performed meta-regression analyses with the last year of recruitment in each study (recruitment closure year) as a continuous covariate. We conducted these meta-regression analyses for the four main ischemic cerebrovascular outcomes and for the outcome of all-cause death. Meta-regression analyses showed that the coefficient of the indicator variable “recruitment closure year” was statistically significantly different than zero for the ipsilateral territory outcomes, indicating that the incidence rates of ipsilateral stroke and ipsilateral stroke or TIA showed statistically significant reduction over time across studies (P<0.001). In contrast, no significant effect of time was detected for any territory cerebrovascular outcomes or the outcome of death (Table 3). The meta-regression plots (Figure 2) provide the log-transformed incidence rates of individual studies plotted against the recruitment closure year of each study and clearly depict a declining trend for the ipsilateral stroke and ipsilateral stroke or TIA outcomes.

Table 3 Meta-regression analysis for the effect of the explanatory variable “recruitment closure year” on the incidence rate of events

Outcome | P-value for the coefficient of “recruitment closure year” | P-value in sensitivity analyses^*^
Ipsilateral stroke | 0.001 | NA
Ipsilateral stroke or TIA | <0.001 | NA
Any stroke | 0.947 | 0.020
Any stroke or TIA | 0.352 | NA (only 4 studies available)
Death | 0.083 | 0.041

NA = not applicable; TIA = transient ischemic attack

* P-value for the coefficient of “recruitment closure year” in sensitivity analysis of studies reporting both ipsilateral and any territory outcomes

Figure 2 Meta-regression of the log-event rates by recruitment closure year for the four major ischemic cerebrovascular outcomes

Each study is depicted by a hollow circle with a size proportional to the number of observed events per outcome. The fitted line is derived from the meta-regression model.

Figure 2 depicts four meta-regression plots that provide the log-transformed incidence rates of individual studies of medical therapy alone plotted against the recruitment closure year of each study as a continuous covariate. The analyses were conducted by report investigators to examine trends over time of the incidence rates of the four main ischemic cerebrovascular outcomes (any stroke, any stroke/transient ischemic attack [TIA], ipsilateral stroke, ipsilateral stroke/TIA). Each study is depicted by a hollow circle with size proportional to the number of observed events per outcome. The fitted line is derived from the meta-regression model. Meta-regression analyses showed that the coefficient of the indicator variable “recruitment closure year” was statistically significantly different than zero for the ipsilateral territory outcomes, indicating that the incidence rates of ipsilateral stroke and ipsilateral stroke or TIA showed statistically significant reduction overtime (P<0.001). The meta-regression plots depict a declining trend for the ipsilateral stroke and ipsilateral stroke or TIA outcomes.

We aimed to explore further why the reduction of incidence rates of ipsilateral events over time was statistically significant whereas the reductions of rates of any territory events or death were not. Given that different studies have been included in the meta-regression analyses for each outcome (depending on the availability of reported outcomes in each study), we performed sensitivity meta-regression analyses for the any territory outcomes and for the outcome of death, by considering only those studies that reported ipsilateral outcomes as well. With this approach, the same literature sample contributed data for the analyses of all outcomes, making the estimates of the coefficient of the indicator variable “recruitment closure year” comparable across analyses. The results are provided in Table 4, below. In these sensitivity analyses, there was evidence that the incidence rates of any stroke and death have shown statistically significant reduction over time (P=0.02 and 0.04, respectively). Thus, at least for those studies that provided data on ipsilateral events, there was significant reduction in the incidence rates of any stroke and death over time.

Table 4 Subgroup meta-analyses for the incidence rates of ipsilateral cerebrovascular outcomes for older studies and recent studies

| Studies with recruitment closure years before 2000 | | Studies with recruitment closure years since 2000
Outcome | N of studies | Summary incidence rate (95% CI) | N of studies | Summary incidence rate (95% CI) | P-value (for interaction)
Ipsilateral stroke | 16 | 0.0231 (0.0187, 0.0285) | 10 | 0.0113 (0.0095 , 0.0134) | <0.001
Ipsilateral stroke or TIA | 13 | 0.0677 (0.0520 , 0.0881) | 7 | 0.0364 (0.0314, 0.0421) | <0.001

CI = confidence interval, TIA = transient ischemic stroke.

In subgroup analysis, we further explored whether recent studies with recruitment closure years since 2000 compared with older studies with recruitment closure years before 2000 provide significantly different estimates of incidence rates of ipsilateral cerebrovascular events. Studies published with recruitment closure years since 2000 were considered to be more representative of contemporary medical therapies.

The summary incidence rate of ipsilateral stroke was significantly decreased in recent studies compared with older studies (0.011 versus 0.023, P for interaction <0.001). Similar results were obtained for the outcome of ipsilateral stroke or TIA (Table 4).

We conducted additional exploratory subgroup analyses by considering the following stratification factors: quality of studies (A or B versus C), operational definitions on the intensity of reported treatment (stratified by the reported proportion of patients under treatment with anti-thrombotic agents [50 percent threshold] or statins [25 percent threshold], extent of anatomical stenosis (>70 percent versus 50-70 percent stenosis) and finally, inclusion of patients with contralateral CEA in the study cohort versus never-operated patients. The results of these analyses are shown in Table 5. For ipsilateral events, quality-A or -B studies resulted in lower point estimates of incidence rates compared with quality-C studies, but no formal statistical comparison was performed. 73 The subgroup of studies with populations with carotid stenosis >70 percent did not result in a significantly higher summary incidence rate of ipsilateral stroke compared with the subgroup of 50-70 percent stenosis (summary incidence rate = 0.024, 95% CI = 0.018, 0.032 vs. summary incidence rate = 0.0161, 95% CI = 0.011, 0.023; P-value for interaction = 0.431). However, severity of stenosis in medically-treated patients was associated with higher summary incidence rates for all other cerebrovascular outcomes, both ipsilateral (ipsilateral stroke or TIA, P = 0.028) or any territory (any stroke, P = 0.019, and any stroke or TIA, P<0.001). Use of statins by more than 25 percent of the study population was associated with significantly decreased rates of ipsilateral stroke compared with use of statins by less than 25 percent of the study population, but had no statistically significant difference in rates of any territory cerebrovascular events or death. Studies that allowed the inclusion of patients with contralateral CEA did not result in increased estimates of incidence rates of ipsilateral stroke and ipsilateral stroke or TIA (P-values for interaction = 0.504 and 0.879, respectively).

Table 5 Subgroup meta-analyses for the incidence rates of cerebrovascular events and death

| | Summary incidence rate (95% CI), number of studies
| Subgroup | Ipsilateral stroke | Ipsilateral stroke or TIA | Any stroke | Any stroke or TIA] | Death
Quality | A or B | 0.0159 (0.0121, 0.0209), n=20 | 0.0455 (0.0379, 0.0547), n=13 | 0.0318 (0.0232, 0.0435), n=12 | 0.0571 (0.0330, 0.0990), n=5 | 0.0438 (0.03, 0.064), n=11
Quality | C | 0.0216 (0.0151, 0.0310), n=6 | 0.0881 (0.0596, 0.1304), n=7 | 0.0147 (0.0080, 0.0270), n=5 | NA, n=4 | NA, n=3
Stenosis | 50-70% | 0.0161 (0.0112, 0.0234), n=11 | 0.0476 (0.0370, 0.0612), n=10 | 0.0205 (0.0099, 0.0423), n=6 | 0.0550 (0.0392, 0.0773), n=6 | NA, n=4
Stenosis | >70% | 0.0237 (0.0175, 0.0321), n=13 | 0.0828 (0.0537, 0.1277), n=12 | 0.0321 (0.0212, 0.0486), n=6 | 0.0775 (0.0645, 0.0932), n=7 | NA, n=4
Statin use | <25% | 0.0236 (0.0189, 0.0295), n=9 | 0.0579 (0.0489, 0.0686), n=8 | 0.0298 (0.0187, 0.0473), n=10 | NA, n=4 | 0.0590 (0.0426, 0.0817), n=7
Statin use | >25% | 0.0108 (0.0060, 0.0193), n=7 | NA, n=3 | 0.0231 (0.0136, 0.0395), n=5 | NA, n=2 | 0.0419 (0.0290, 0.0607), n=5
Anti-platelets use | <50% | NA, n=0 | NA, n=0 | NA, n=2 | NA, n=2 | NA, n=1
Anti-platelets use | >50% | 0.0163 (0.0117, 0.0227), n=16 | 0.0492 (0.0403, 0.0599), n=11 | 0.0285 (0.0194, 0.0420), n=13 | 0.0529 (0.0277, 0.1009), n=4 | 0.0509 (0.0378, 0.0685), n=11
Contralateral CEA | None | 0.0169 (0.0124, 0.0231), n=18 | 0.0552 (0.0398, 0.0765), n=13 | 0.0262 (0.017, 0.0400), n=13 | 0.0552 (0.0383, 0.0796), n=8 | 0.0466 (0.0324, 0.067), n=11
Contralateral CEA | Yes | 0.0165 (0.0121-0.0226), n=7 | 0.0525 (0.0416, 0.0663), n=6 | NA, n=4 | NA, n=1 | NA, n=2

CI = confidence interval, n = number, NA = not applicable.

In a sensitivity analysis, we considered only data derived from Kaplan-Meier analyses, either extracted from published figures following digitization or by using the reported incidence rates (95% CI) in each study. In a random-effects meta-analysis, the summary incidence rates obtained for each outcome were of similar magnitude to the summary estimates obtained in the main analysis of numerical data (summary incidence rate of ipsilateral stroke = 0.019, 95% CI = 0.010, 0.028, n=7 studies; summary incidence rate of ipsilateral stroke or TIA = 0.052, 95% CI = 0.029, 0.075, n=3 studies; summary incidence rate of any stroke = 0.041, 95% CI = 0.014, 0.067, n=3 studies; summary incidence rate of any stroke or TIA = 0.061, 95% CI = 0.054, 0.069, n=7 studies; summary incidence rate of death = 0.066, 95% CI = 0.037, 0.094, n=3 studies).

#### Sensitivity analyses

We conducted sensitivity analyses of quality-A and -B studies of medical therapy alone. In 20 quality-A and -B studies, the summary incidence rate of ipsilateral stroke in asymptomatic patients on (any) medical therapy alone was 1.59 (95% CI = 1.21, 2.09) percent per year of followup. The summary incidence rate estimate of 13 studies reporting the combined outcome of ipsilateral stroke or transient ischemic attack (TIA) was 4.56 (95% CI = 3.79, 5.47) percent per year of followup. The summary incidence rate for any stroke in 12 studies was 3.18 (95% CI = 2.32, 4.35) and for any stroke or TIA in five studies was 5.71 (95% CI = 3.30, 9.90) percent per year of followup. The summary incidence rate of all-cause death across 11 studies was 4.38 (95% CI = 3.00, 6.41) percent per year of followup. The summary incidence rate of ipsilateral stroke was significantly decreased in recent studies (recruitment closure between 2000 and 2010) as compared with older studies with recruitment closure before 2000 (1.13 versus 2.38 percent per year, P for interaction = 0.0008).

In contrast to our main analyses, a significant effect of time was detected for all cerebrovascular outcomes, including any stroke and any stroke or TIA.

#### Applicability

Medical therapy alone studies, specifically studies with recruitment closure year since 2000 were deemed applicable to contemporary clinical practice. However, no separate data were available by the age subgroups ≥ 65 years and ≥ 80 years. Furthermore, no separate subgroup data were available by sex and baseline comorbid medical conditions other than data for subgroup analysis by contralateral CEA, and clinical or anatomic features of carotid artery stenosis (>70 percent).

#### Summary of Key Question 1a (Effectiveness of medical therapy alone)

There is moderate strength of evidence among 20 quality-A and -B studies that medical therapy alone can reduce the incidence rate of ipsilateral stroke over time in patients with asymptomatic carotid stenosis. Meta-regression analyses of quality-A and -B studies showed that the incidence rates of ipsilateral stroke, ipsilateral stroke or TIA, any territory stroke, and death significantly decreased between 2000 and 2010 as compared with older studies (those with recruitment closure year before 2000). The summary incidence rate of ipsilateral stroke was significantly decreased in recent studies compared with older studies (1.13 versus 2.38, P=0.0008). In contrast, inclusion of all studies regardless of their methodological quality resulted in reduction of incidence rates of ipsilateral stroke and ipsilateral stroke or TIA, but not for any territory stroke or death.

### Key Question 1 (Comparison of Treatments and Long-term Outcomes)

#### CEA and medical therapy versus medical therapy alone

Data for the comparison of CEA and medical therapy with medical therapy alone for efficacy and safety endpoints (Key Questions 1–3) were contributed by three RCTs and seven nonrandomized comparative studies. In the following section, the design characteristics of these 10 studies are described in detail (Table 6). The results of these studies are then presented according to which key question is addressed by each study.

Table 6 Summary characteristics of studies comparing CEA versus medical therapy

Study | N subjects (followup yr) | Diagnosis of carotid stenosis | Percent carotid stenosis | Primary endpoint (long-term) | Perioperative outcome
RCT
VA 1993^32^ | 444 (3.9 ) | DUS; OPG DSA | ≥ 50% stenosis NASCET criteria | Composite of ipsilateral TIA, stroke, and death | TIA, stroke, MI, death, cranial nerve injuries
ACAS 1995^28^ | 1659 (2.7) | CEA: DSA Medical: DUS | ≥ 60% stenosis NASCET criteria | Composite of ipsilateral stroke and death | Stroke, MI, death
ACST 2004, 2010^*,30,31^ | 3120 (10) | DUS | ≥ 60% stenosis ECST criteria | Composite: perioperative mortality, morbidity, and nonperioperative stroke | Stroke, MI, death
NRCS (Prospective)
CASANOVA 1991^60^ | 233 (3) | DUS; DSA | 50 – 90% stenosis; NASCET criteria | Composite: ipsilateral stroke and death | None
Mayo 1992^59^ | 158 (2) | DUS or DSA | ≥ 50% stenosis NASCET criteria | Composite of TIA, stroke, and death | TIA, stroke, and death
NRCS (Retrospective)
Libman 1992^74^ | 215 (5) | DUS | ≥ 50% stenosis (criteria: nd) | Ipsilateral stroke or stroke free survival | Stroke
Hertzer 1986^75^ | 290 (∼3) | DSA | ≥ 50% stenosis (criteria: nd) | TIA, stroke, and death | Stroke, death
Poulias 1994^76^ | 134 (5.2) | No data | ≥ 60% stenosis (criteria: nd) | Stroke or death | Stroke, death
Caracci 1989^77^ | 141 (∼2) | DUS | ≥ 75% stenosis (criteria: nd) | TIA, stroke, and death | Stroke, death
Bosiers 2005^78^ | 36 (30 d) | No data | ≥ 80% stenosis (criteria: nd) | None | Stroke, death
Ogata 2012 | 93 (4.2) | DSA | ≥ 80% stenosis (criteria: nd) | Stroke, MI, and death | Stroke, death

ACAS = Asymptomatic Carotid Atherosclerosis Study; ACST = Asymptomatic Carotid Surgery Trial, DSA = digital subtraction angiography, DUS = duplex ultrasonography, ECST = European Carotid Surgery Trial, MI, myocardial infarction, NASCET = North American Symptomatic Carotid Endarterectomy Trial, nd = not documented, NRCS, nonrandomized comparative study, OPG = ocular pneumoplethysmography, RCT = randomized controlled trial, TIA = transient ischemic attack, VA = Veterans Affairs Cooperative Study.

* Includes patients with remote (>6 months) ipsilateral carotid territory symptoms.

#### Study characteristics

##### Randomized controlled trials

Three quality-A RCTs, the Veterans Affairs Cooperative Study (VA), the Asymptomatic Carotid Atherosclerosis Study (ACAS), and the Asymptomatic Carotid Atherosclerosis Trial (ACST), compared CEA with medical therapy and met our inclusion criteria.28,30,32 A total of 5,223 patients were randomized to either CEA (2,659 patients) or to medical therapy (2,627 patients). While the VA trial compared CEA with medical therapy, ACAS and ACST compared immediate CEA with deferred CEA, in which the deferred CEA group was managed with “standard of care” medical therapy. Patients allocated to the deferred group did not undergo CEA unless they had subsequent ipsilateral or carotid territory symptoms of TIA or stroke (i.e. progressed from asymptomatic state to symptomatic state). All three trials were multicenter. The VA trial recruited adult men from 11 VA hospitals in the U.S. from 1983 -1987. The VA trial recruited 444 eligible patients of the target sample of 500 patients, whereas ACAS and ACST achieved their target sample size. ACAS recruited adults (approximately two-thirds men and one-third women) between the ages of 40 and 79 years in the U.S. and Canada from 1987-1993. ACST recruited adults (approximately two-thirds men and one-third women) from 30 different countries from 1993–2003 and had two long-term (5 and 10 year) followup publications.30,31

###### Eligibility criteria and diagnosis of asymptomatic carotid stenosis

All three trials excluded patients who were at high medical risk for CEA due to associated medical illnesses or those who had contraindications to aspirin therapy. Both the VA trial and ACAS included patients without prior ipsilateral neurological symptoms, while ACST included patients with remote (> 6 months) ipsilateral carotid territory symptoms.

The methods to diagnose asymptomatic carotid stenosis as well as the degree of asymptomatic carotid stenosis as the inclusion criteria differed across three RCTs (Table 6). This included different diagnostic methods to evaluate the degree of carotid stenosis. ACST recruited 99 patients with stenosis < 60 percent based on their perceived need for an intervention or if they had a carotid stenosis with a soft plaque as defined by DUS.

###### Population

Baseline characteristics of the enrolled patients varied considerably in all three trials. All three RCTs included some proportion of patients with contralateral cerebrovascular symptoms. Both ACAS (20 percent) and ACST (24 percent) enrolled participants who had undergone CEA for contralateral carotid artery stenosis, while the VA trial excluded these patients. A higher percentage of participants had atrial fibrillation, contralateral carotid occlusions, and history of smoking in the VA trial compared with ACAS or ACST. Among included patients, contralateral carotid occlusions were present in 32 percent in the VA trial, but approximately 10 percent in both ACAS and ACST. In ACAS, almost 70 percent of participants had a history of CAD, which was much higher than in the VA trial (30 percent) or ACST (5 percent).

###### Interventions

All three trials required performance certification for the surgeons performing the CEA. In the VA trial each surgeon was required to provide performance records for the last 2 years. In ACAS surgeons were required to perform a minimum of 12 CEA per year with a mortality/morbidity < 3 percent in the last 50 CEAs. In the ACST trial, each surgeon was required to submit a record of their last 50 CEAs, specifically the number of CEAs for asymptomatic carotid stenosis, and the events of morbidity/mortality occurring within 30 days. There was no report on the volume of each recruiting center. Across the many centers in each trial, there were no attempts to standardize surgical or anesthetic techniques. Details of surgical techniques lacked clear reporting. In ACAS, “selective shunt” to avoid cerebral hypoperfusion or technical variations, such as “patching of the endarterectomy site” or “eversion CEA” was used at the discretion of individual surgeons, while the other two trials did not report any technical data. Patients randomly assigned to CEA underwent surgery within 10 days in the VA trial or within 14 days in ACAS. In ACST, after randomization, no particular time frame for surgery was reported in the immediate CEA group, but participants underwent CEA surgery as soon as possible. In the same study, of those patients allocated to the immediate CEA group, 50 percent had ipsilateral CEA by 1 month, 88 percent by 1 year, and 91 percent by 5 years.

###### Comparators and co-medications

Across all three trials, medical treatments were left to the discretion of individual treating physicians with antiplatelet therapy being the most commonly prescribed medical therapy in both the intervention groups. Of note, the VA trial used a very high daily dose of aspirin (650 mg twice daily), while ACAS and ACST used a dosage of aspirin 325 mg daily. All studies reported the use of appropriate medical therapy for both groups, although ACST “optimized” and also standardized medical therapy for all patients using specific thresholds to control hypertension, lipid levels, and diabetes. Both ACAS and ACST provided additional information on the use of smoking cessation programs, and medications to control hypertension, lipid levels, and diabetes. Additionally, ACAS counseled participants against the use of alcohol or estrogen compounds. A recently published 10 year followup of ACST reported an increased use of lipid-lowering medications in the later years of followup up to 80 percent, compared to the use of these medications by only 10 percent of patients at study entry. Patients allocated to the medical therapy group crossed over to the surgical group and underwent CEA under the following conditions: if they had a TIA in the VA trial, if they had ipsilateral symptoms of TIA or stroke in ACAS, and if they had any carotid territory symptoms of TIA or stroke in ACST.

###### Outcomes

The average followup in the VA trial was 4 years, and the median followup in ACAS and ACST were 2.7 years and 9 years, respectively. The primary endpoint in each trial is listed in Table 6. Based on the results of the VA trial, the primary endpoint of ACAS was modified and TIA was excluded as an outcome of interest. In all three trials, neurologists assessed the stroke outcomes and stroke was classified based on location and etiology. The VA trial classified stroke outcomes as established by the Advisory Council of the National Institutes of Neurological and Communicative Disorders and Stroke and allowed patients with TIA to crossover to the CEA group. ACAS used the Glasgow Outcome scale (2 to 5) and ACST used a Rankin score 3 or greater for stroke severity classification; both trials allowed patients with stroke to crossover to the immediate CEA group.

###### Study quality

All were rated quality-A trials as they met most of our predefined methodological criteria. All three multicenter trials used central randomization. About 15 percent of recruited patients refused to participate in the VA trial and there was unclear reporting of patients with TIA that crossed over to the CEA group. The proportion of patients who failed to undergo surgery in the CEA group after randomization ranged from 4 percent in the VA trial, 12 percent in ACAS, and 10 percent in ACST. All trials were evaluated using intention-to-treat analysis. ACAS reported interim benefit of CEA over medical therapy, so that the trial was stopped after a median of 2.7 years of the 5-year target followup. Other problems with the conduct of the trials were encountered: 1) the VA trial patients did not adhere to high dose of aspirin up to 650 mg twice daily (16 percent discontinued aspirin and 27 percent took aspirin 325 mg daily); and when ACAS was nearing its completion and patients had already undergone therapy, the trial authors had modified their primary outcome by excluding TIA from their primary endpoint after the VA trial was published.

##### Nonrandomized comparative studies

Two quality-B prospective and five quality-C retrospective nonrandomized comparative studies compared CEA versus medical therapy met our inclusion criteria.59,60,74-78 All studies were conducted in the 1980's through the early 1990's except for one recently published study by Bosiers 2005, which retrospectively reviewed their 2003 data.78

###### Prospective studies

CASANOVA was a multicenter RCT among patients with asymptomatic carotid stenosis. By using a posthoc nonrandomized design, the authors reported the efficacy of CEA and medical therapy compared with medical therapy alone in patients with asymptomatic carotid stenosis. The trial was conducted in the Germany among 410 patients with asymptomatic carotid stenosis ≥ 50 percent.60 The degree of stenosis was diagnosed by DUS and confirmed by angiography, both using NASCET criteria. Patients with > 90 percent stenosis were excluded and the trial used several treatment strategies including unilateral or bilateral CEA, and unilateral CEA or medical therapy. The medical therapy included daily doses of aspirin 300 mg plus dipyridamole 75 mg. CEA was performed frequently in patients with bilateral stenosis >50 percent who had been assigned to the medical therapy group. As high as 18 percent of randomized patients did not comply with the study protocol. The trial was stopped early when it became increasingly difficult to convince patients to undergo CEA.

The Mayo Clinic trial, a multicenter RCT conducted in the USA that compared CEA with aspirin (80 mg) was terminated early due to increased events of MI in the CEA group; but the trial continued to add eligible patients recruited through a nonrandomized design.59 This RCT enrolled asymptomatic patients with > 50 percent stenosis diagnosed by DUS. The CEA group was not allowed to receive aspirin therapy, and only patients who were prescribed aspirin for prior cardiac disease were allowed to continue aspirin therapy. The trial excluded patients with atrial fibrillation, prior TIA or CEA, and contralateral occlusion. Higher rates of MI and TIA in the CEA group resulted in an early termination after only 71 patients were enrolled. The study added 87 eligible nonrandomized patients with addition of aspirin therapy in both groups and a total of 158 patients were followed for 2 years. The primary endpoint of the trial was TIA, any stroke or death. The study was inconclusive for the outcomes of interest.

###### Retrospective studies

Six retrospective studies evaluated CEA versus medical therapy in a total of 909 patients with asymptomatic carotid stenosis. All studies were conducted in the 1980's through the early 1990's except for two recently published studies.78,79 Three studies included carotid stenosis >50 or > 60 percent stenosis as diagnosed by DSA75 and DUS,74,77 one included ≥80 percent stenosis as measured by DSA,79 while one study did not report its method of diagnosis. The Bosiers 2005 study reported only perioperative outcomes and is further discussed in Key Question 3. The majority of patients included in the remaining four studies were≥ 65 years of a ge. These studies provided no data or excluded patients who were at high risk for CEA.

### Key question 1b (Long-term outcomes 12 months or greater)

#### Ipsilateral stroke (including any stroke or death within 30 days)

##### RCTs of CEA versus medical therapy

All three RCTs contributed to the analysis of ipsilateral stroke (defined as any stroke or death within 30 days or subsequent ipsilateral stroke). In individual trials, ipsilateral stroke were lower in the CEA compared the medical therapy, which reached statistical significance only in ACAS. In a meta-analysis (Figure 3), the CEA had a 31 percent significantly decreased risk of ipsilateral stroke (including perioperative stroke or death) as compared with the medical therapy (summary RR = 0.69, 95% CI = 0.55, 0.87) without statistical heterogeneity (I^2^ = 0.0%, P =0.90).

Figure 3 Meta-analysis of ipsilateral stroke in studies of CEA versus medical therapy

CEA = carotid endarterectomy; CI = confidence interval; Med = medical therapy; NRCS = nonrandomized comparative study; RCT = randomized controlled trial; RR = risk ratio

RR <1 favors CEA and medical therapy compared with medical therapy alone

Figure 3 is a meta-graph of random effects analysis of the outcome of ipsilateral strokes in three randomized controlled trials (Veteran's Affairs Cooperative Study 1993, Asymptomatic Carotid Atherosclerosis Study 1995, Asymptomatic Carotid Atherosclerosis Trial 2010) and three nonrandomized comparative studies [Mayo 1992, prospective; Libman 1994, retrospective; Caracci 1989, retrospective] of carotid endarterectomy (CEA) versus medical therapy. The graph provides relative risk (RR) and associated confidence intervals (CI) as well as a column each for number of stroke events in both CEA and medical therapy groups from each study. Summary results for the RCTs are as follows: RR = 0.72, 95% CI = 0.58, 0.90 without heterogeneity (I2 = 0.0%, P = 0.810) [VA 1993, RR = 0.75, 95% CI = 0.42, 1.35; ACAS 1995, RR = 0.64, 95% CI = 0.42, 0.98; ACST 2010, RR= 0.76, CI = 0.57, 1.01. Individual results from the nonrandomized comparative studies are as follows: Mayo 1992, RR = 5.29, 95% CI = 0.61, 46.30; Libman 1994, RR = 1.47, 95% CI = 0.48, 4.48; Caracci 1998, RR = 0.14, 95% CI = 0.03, 0.62. Summary relative risk for these studies is 0.94 with heterogeneity (I2 = 78.8%, P = 0.009).

##### Other comparative studies of CEA versus medical therapy

One quality-B prospective and two additional quality-C retrospective comparative studies contributed to the meta-analysis of ipsilateral stroke that showed no significant difference between CEA and medical treatment (summary RR = 0.78, 95% CI = 0.12, 4.87) with a very wide confidence interval and statistically significant heterogeneity (I^2^ = 77%, P=0.01). Mayo 1992 with an average followup of 2 years reported that more patients in the CEA (who were precluded from aspirin therapy) had ipsilateral stroke than the medical therapy group (who were treated with a low dose of 80 mg/day aspirin). Libman 1994 followed 215 patients for an average of 3.8 years and the study had high periprocedural adverse events in the CEA group that resulted in higher risk of ipsilateral stroke compared to the medical therapy group (RR = 1.47, 95% CI = 0.48, 4.48). Caracci 1989 followed 141 patients for an average of 2 years and reported significantly decreased risk of ipsilateral stroke in the CEA group compared with the medical therapy group (RR = 0.13, 95% CI = 0.03, 0.55).

#### Any stroke (including any death within 30 days)

##### RCTs of CEA versus medical therapy

All three RCTs reported data on occurrence of any stroke, irrespective of location, cause, or type of stroke. The outcome of any stroke was defined as events of perioperative stroke or death or nonperioperative any territory stroke. Both ACAS and ACST reported statistically significant reduction in the risk of any stroke for CEA over medical therapy, while the VA trial did not. In a meta-analysis (Figure 4), the CEA had a 32 percent significantly decreased risk of any stroke (including perioperative stroke or death) as compared with the medical therapy (summary RR = 0.68, 95% CI = 0.56, 0.82) without statistical heterogeneity (I^2^ = 17.7%, P=0.30).

Figure 4 Meta-analysis of any stroke in studies of CEA versus medical therapy

CEA = carotid endarterectomy; CI = confidence interval; Med = medical therapy; NRCS = nonrandomized comparative study; RCT = randomized controlled trial; RR = risk ratio

RR <1 favors CEA and medical therapy compared with medical therapy alone

Figure 4 is a meta-graph of random effects analysis of the outcome of any stroke (both peri- and postoperative strokes of any cause and location) in three randomized controlled trials (Veteran's Affairs Cooperative Study 1993, Asymptomatic Carotid Atherosclerosis Study 1995, and Asymptomatic Carotid Atherosclerosis Trial 2010) and three nonrandomized comparative studies [Mayo 1992, prospective; Hertzer 1986, retrospective; Libman 1994, retrospective] of carotid endarterectomy (CEA) versus medical therapy. The graph provides relative risk (RR) and associated confidence intervals (CI) as well as a column each for number of stroke events in both CEA and medical therapy groups from each study. Summary results for the RCTs are as follows: RR = 0.68, 95% CI = 0.56, 0.82, without heterogeneity (I2 = 17.7%, P = 0.297)) [VA 1993, RR = 0.92, 95% CI = 0.56, 1.51; ACAS 1995, RR = 0.71, 95% CI = 0.51, 0.97; ACST 2010, RR = 0.61, 95% CI = 0.49, 0.76]. Results for the nonrandomized comparative studies were inconclusive with heterogeneity (I2 = 51.5%, P = 0.127) [Mayo 1992, RR = 6.62, 95% CI = 0.79, 55.34; Hertzer 1986, RR = 0.57, 95% CI = 0.17, 1.89; Libman 1994, RR = 0.80, 95% CI = 0.41, 1.57].

##### Noncomparative studies of CEA versus medical therapy

Any stroke in nonrandomized comparative studies showed no significant difference between the treatment groups (summary RR = 1.01, 95% CI = 0.37, 2.73) with statistically nonsignificant heterogeneity (I^2^ = 51.5%, P=0.13).

#### Any stroke or death

##### RCTs of CEA versus medical therapy

All three RCTs reported a nonsignificantly decreased risk for the combined endpoint of any stroke or death in the CEA as compared with the medical therapy. A meta-analysis (Figure 5) showed no significant difference between the two groups (summary RR = 0.94, 95% CI = 0.85, 1.03) without statistical heterogeneity (I^2^ = 19%, P=0.29).

Figure 5 Meta-analysis of any stroke or death in studies of CEA versus medical therapy

CEA = carotid endarterectomy; CI = confidence interval;Med = medical therapy; NRCS = nonrandomized comparative study; RCT = randomized controlled trial; RR = risk ratio

RR <1 favors CEA and medical therapy compared with medical therapy alone

Figure 5 is a meta-graph of random effects analysis of the outcomes of any stroke or death in three randomized controlled trials (RCTs) [Veteran's Affairs Cooperative Study 1993, Asymptomatic Carotid Atherosclerosis Study 1995, and Asymptomatic Carotid Atherosclerosis Trial 2010] and two prospective, nonrandomized comparative studies [Mayo 1992, CASANOVA 1991] of carotid endarterectomy (CEA) versus medical therapy. The graph provides relative risk (RR) and associated confidence intervals (CI) as well as a column each for number of any stroke or death events in both CEA and medical therapy groups from each study. Summary results for the RCTs are as follows: RR = 0.94, 95% CI = 0.85, 1.03, without heterogeneity (I2 = 19%, P = 0.290) [VA 1993, RR = 0.93, 95% CI = 0.75, 1.16; ACAS 1995, RR = 0.81, 95% CI = 0.65, 1.00; ACST 2010, RR = 0.97, 95% CI = 0.90, 1.05]. Summary results for the nonrandomized comparative studies are as follows: RR = 1.34, 95% CI = 0.34, 5.28, with heterogeneity (I2 = 61%, P = 0.107) [Mayo 1992, RR = 3.31, 95% CI = 0.66, 16.54; CASANOVA 1991, RR = 0.78, 95% CI = 0.38, 1.61).

##### Nonrandomized comparative studies of CEA versus medical therapy

In nonrandomized comparative studies, a meta-analysis showed nonsignificant increase in the risk of any stroke or death in the CEA group over the medical therapy group (summary RR = 1.34, 95% CI = 0.34, 5.28). In view of heterogeneity (I^2^ = 61%, P=0.11) even though it was not statistically significant, this requires cautious interpretation. CASANOVA 1991 was terminated when the endpoint of stroke or death was reached in 9.8 percent of 122 patients who had CEA compared with 12.6 percent of 111 patients who had medical therapy alone (P = 0.32).

#### Death

##### RCTs of CEA versus medical therapy

All three RCTs reported data on overall death. ACST with the longest followup of almost 10 years reported more deaths due to cancer and other related illnesses than the VA trial and ACAS, each with an average followup of 4 years and 2.7 years, respectively. A meta-analysis of the three RCTs showed no significant difference in death between the two intervention groups (summary RR = 1.05, 95% CI = 0.85, 1.03). There was no statistical heterogeneity (I^2^ = 0.0%, P=0.60) (Figure 6). When the meta-analysis was restricted to fatal stroke (Figure 7) or by CVD related deaths (Figure 8), it resulted in similar results.

Figure 6 Meta-analysis of any death in studies of CEA versus medical therapy

CEA = carotid endarterectomy; CI = confidence interval; Med = medical therapy; RR = risk ratio

RR <1 favors CEA and medical therapy compared with medical therapy alone

Figure 6 is a meta-graph of random effects analysis of the overall outcome of death in three randomized controlled trials (RCTs) [Veteran's Affairs Cooperative Study 1993, Asymptomatic Carotid Atherosclerosis Study 1995, and Asymptomatic Carotid Atherosclerosis Trial 2010] of carotid endarterectomy (CEA) versus medical therapy. The graph provides relative risk (RR) and associated confidence intervals (CI) as well as a column each for number of events in both CEA and medical therapy groups from each study. Meta-analysis using the ACST-1 2004 (5 year followup) study resulted in no significant difference between two groups (summary RR = 0.94, 95% CI = 0.80, 1.10) with heterogeneity (I2 = 48.2%). A meta-analysis of RCTs with the ACST-1 2010 (10 year followup) resulted in a slight non-significant increase in death in the CEA group over the medical group (summary RR = 1.05, 95% CI = 0.97, 1.14) without heterogeneity (I2 = 0.0%, P = 0.603) [VA 1993, RR = 1.03, 95% CI = 0.80, 1.34; ACAS 1995, RR = 0.92, 95% CI = 0.70, 1.22; ACST 2010, RR = 1.07, 95% CI = 0.98, 1.17]

Figure 7 Meta-analysis of fatal stroke in studies of CEA versus medical therapy

CEA = carotid endarterectomy; CI = confidence interval; Med = medical therapy; RCT = randomized controlled trial; RR = risk ratio

RR <1 favors CEA and medical therapy compared with medical therapy alone

Figure 7 is a meta-graph of random effects analysis of the outcome of fatal strokes in three randomized controlled trials [Veteran's Affairs Cooperative Study 1993, Asymptomatic Carotid Atherosclerosis Study 1995, and Asymptomatic Carotid Atherosclerosis Trial 2010] of carotid endarterectomy (CEA) versus medical therapy. The graph provides relative risk (RR) and associated confidence intervals (CI) as well as a column each for number of events in both CEA and medical therapy groups from each study. Summary results are as follows: RR = 0.79, 95% CI = 0.57, 1.08. Individual results are as follows: VA 1993, RR = 0.28, 95% CI = 0.03, 2.45; ACAS 1995, RR = 0.91, 95% CI = 0.37, 2.23; ACST 2010, RR = 0.79, 95% CI = 0.56, 1.11.

Figure 8 Meta-analysis of CVD deaths in studies of CEA versus medical therapy

CEA = carotid endarterectomy; CI = confidence interval; Med = medical therapy; RR = risk ratio

RR <1 favors CEA and medical therapy compared with medical therapy alone

Figure 8 is a meta-graph of random effects analysis of the outcome of cardiovascular death outcomes in three randomized controlled trials [Veteran's Affairs Cooperative Study 1993, Asymptomatic Carotid Atherosclerosis Study 1995, and Asymptomatic Carotid Atherosclerosis Trial 2010] of carotid endarterectomy (CEA) versus medical therapy. The graph provides relative risk (RR) and associated confidence intervals (CI) as well as a column each for events in both CEA and medical therapy groups from each study. Summary results are as follows: RR = 1.01, 95% CI = 0.82, 1.25, with heterogeneity (I2 = 37.6%, P = 0.201). Individual results are as follows: VA 1993, RR = 1.03, 95% CI = 0.72, 1.49; ACAS 1995, RR = 0.75, 95% CI = 0.49, 1.13; ACST 2010, RR = 1.12, 95% CI = 0.96, 1.30.

##### Nonrandomized comparative studies of CEA versus medical therapy

In contrast, three nonrandomized comparative studies assessed outcomes of death and all studies reported an increase in death in the medical therapy group compared to the CEA group.59,76,77 Both Mayo 1992 and Poulias 1994 reported no events in the medical therapy group, while Caracci 1989 reported statistically significant increase in deaths in the medical therapy group over the CEA group (24 percent versus 9 percent, P <0.05) Ogata 2012 reported a nonsignificant increase in deaths in the medical therapy group over the CEA group (17 percent versus 37 percent, P = 0.20).

#### CVD outcomes

##### RCTs of CEA versus medical therapy

A meta-analysis using data from all three RCTs resulted in no significant difference in CVD deaths in the CEA as compared with the medical therapy (summary RR = 1.01, 95% CI = 0.82, 1.25) with statistically nonsignificant heterogeneity (I^2^ = 37.6%, P=0.20)

##### Nonrandomized comparative studies of CEA versus medical therapy

Ogata 2012 reported a nonsignificant increase in MI in the medical therapy group over the CEA group (35 percent versus 20 percent, P = 0.75)..

#### Composite endpoint including ipsilateral stroke

##### RCTs of CEA versus medical therapy

All three RCTs reported composite endpoints of within 30-day stroke or death and subsequent ipsilateral stroke. In individual studies, ipsilateral stroke were decreased in the CEA group compared with the medical therapy group, which reached statistical significance only in ACAS trial. In a meta-analysis (Figure 9), the CEA had a 28 percent significantly decreased risk of ipsilateral stroke (including perioperative stroke or death) as compared with the medical therapy (summary RR = 0.72, 95% CI = 0.58, 0.90) without statistical heterogeneity (I^2^ = 0.0%, P = 0.810).

Figure 9 Meta-analysis of composite endpoint of within 30-day stroke or death and subsequent ipsilateral stroke in studies of CEA versus medical therapy

CEA = carotid endarterectomy; CI = confidence interval; Med = medical therapy; NRCS = nonrandomized comparative study; RCT = randomized controlled trial; RR = risk ratio

RR <1 favors CEA and medical therapy compared with medical therapy alone

Figure 9 is a meta-graph of analysis of the composite endpoint of within 30-day stroke or death and subsequent ipsilateral stroke in studies of CEA versus medical therapy. The graph provides relative risk (RR) and associated confidence intervals (CI) as well as a column each for events in both CEA and medical therapy groups from each study. In meta-analysis of three randomized controlled trials (Veteran's Affairs Cooperative Study 1993, Asymptomatic Carotid Atherosclerosis Study 1995, and Asymptomatic Carotid Atherosclerosis Trial 2010) the CEA group had 28 percent lower risk of ipsilateral stroke (including perioperative stroke or death) compared with the medical group (summary RR = 0.72, 95% CI = 0.58, 0.90) without statistically significant heterogeneity (I2 = 0.0%, P = 0.810). Analysis of an additional three retrospective comparative studies contributed to the analysis of ipsilateral stroke and found a lack of significant differences between CEA and medical therapy in the presence of statistically significant heterogeneity (I2 = 78.8%, P=0.009).

##### Nonrandomized comparative studies of CEA versus medical therapy

One quality-B prospective and two quality-C retrospective comparative studies found no significant differences between CEA and medical therapy for the risk of ipsilateral stroke (summary RR = 0.94, 95% CI = 0.14, 6.42), but with statistically significant heterogeneity (I^2^ = 78.8%, P=0.009).

##### Summary of Key Question 1b (Effectiveness of CEA and medical therapy versus medical therapy alone on long-term outcomes)

Three quality-A RCTs demonstrated a reduction in the risk of ipsilateral stroke with CEA and medical therapy compared with medical therapy alone. The strength of evidence is graded as moderate, but their results may not be applicable to contemporary clinical practice. In these trials, patients with asymptomatic carotid stenosis did not receive at randomization what is considered current best medical therapy, including healthy life-style habits and the use of optimized therapy such as statins and targets for the treatment of blood pressure and diabetes. The trials showed no difference between the two treatment groups for the risk of any death, fatal stroke, or CVD death. It is important to note that, all trials were conducted during 1990–2000 and used “standard of care” medical therapy that was considered appropriate for the management of patients with asymptomatic carotid stenosis during that period. Additionally, two prospective and six retrospective nonrandomized comparative studies compared CEA versus medical therapy. In contrast to the RCTs, nonrandomized comparative studies showed no significant difference in ipsilateral stroke between the two treatment groups. In view of wide confidence intervals of the summary estimate and statistically significant heterogeneity, the results of nonrandomized comparative studies need cautious interpretation.

#### CAS and medical therapy versus medical therapy alone

There were no eligible RCTs for the comparison of CAS and medical therapy with medical therapy alone. Two (one quality-B, one quality-C) nonrandomized comparative studies met our inclusion criteria.

#### Study characteristics

##### Nonrandomized comparative studies

Two (one quality-B, one quality-C) nonrandomized comparative studies met our inclusion criteria that compared CAS and medical therapy with medical therapy alone.78,80 A total of 1,021 patients received either CAS (480 patients) or medical therapy (541 patients). Both of the studies were single center registries and analyzed retrospectively. The Sherif 2005 study attempted to balance the observed clinical characteristics in the two intervention groups by applying a propensity score-matched analysis, and was rated quality-B, while the Bosiers 2005 study, with no adjusted analyses, was rated quality-C.

The degree of carotid stenosis differed between the two studies. Sherif 2005study included patients with ≥ 70 percent asymptomatic carotid stenosis diagnosed by DUS, using the NASCET criteria. The ultrasound measurements were validated by angiography in an independent sample. Bosiers 2005 study included patients with ≥ 80 percent asymptomatic carotid stenosis, but no information was documented on the diagnostic modality. Followup periods were also different between the two studies. The Sherif 2005 study followed patients for a median of 25 months (absolute range, 6 to 72 months), while Bosiers 2005 study followed patients for only 30 days.

In the Sherif 2005 study, medical therapy in both groups included antiplatelet therapy with aspirin or clopidogrel and recommended lipid-lowering therapy with statins for patients with hyperlipidemia. Data on medical therapy were not reported in the Bosiers 2005 study.

Baseline characteristics are shown in Appendix E, Table 8. The Sherif 2005 study included patients with an average age of 72.5 years, and the proportion of males was 68 percent. The percentages of patients with vascular risk factors were hypertension (76.5 percent), hyperlipidemia (76.5 percent), diabetes mellitus (35.5 percent), and current smoking status (18 percent). About 44.5 percent of patients had coronary artery disease. None of the patients in this study had a history of prior cerebrovascular events or previous CAS or CEA. Fifteen percent of the patients enrolled in the CAS group had contralateral carotid artery occlusion compared with 6 percent in the medical therapy group. During the followup period in the Sherif 2005 study, 17 percent (88 patients) of patients initially recruited into the medical therapy group crossed over to the CAS group.

No baseline characteristics were provided in the Bosiers 2005 study. Neither study reported data on patients above 80 years of age.

###### Study outcomes and outcome ascertainment

The primary endpoint in the Sherif 2005 study was any stroke or death using Kaplan-Meier estimates for a projected 5 years of followup. The primary endpoint for the Bosiers 2005 study was any stroke or death during periprocedural 30-day period. Neurologic evaluation was performed at baseline in both studies. After intervention in the Bosiers 2005 study, a multi-disciplinary team managed the patients.

In the Sherif 2005 study, patients were followed clinically and by DUS at 6 and 12 months after their initial visit and then annually. A followup survey questionnaire was sent to all patients to assess the occurrence of study endpoints (stroke or death). Neurologic evaluation and mandatory cranial CT were done for all patients with events. Two observers who were unaware of the baseline laboratory data assessed outcomes independently. The Bosiers 2005 study did not provide information on outcome assessment.

### Key Question 1c (Long-term outcomes 12 months or greater)

The outcome data are summarized in Appendix E, Table 9. The Sherif 2005 study was the only one reporting on long-term adverse clinical outcomes for this comparison of CAS and medical therapy with medical therapy alone. This study did not report outcomes of ipsilateral stroke outcomes.

#### Any stroke

The Sherif 2005 study reported an overall significantly decreased risk of any stroke in the CAS group compared with the medical therapy group (adjusted hazard ratio [HR] = 0.47, 95% CI = 0.24, 0.90).

#### Death

The Sherif 2005 study reported a significantly decreased risk of death in the CAS group compared with the medical therapy group (adjusted HR = 0.67, 95% CI = 0.46, 0.97).

#### Any stroke or death

The Sherif 2005 study followed 946 patients for an average of 5 years and reported a significantly decreased risk of any stroke or death in the CAS group compared with the medical therapy group (adjusted HR = 0.66, 95% CI = 0.47, 0.91).

#### Summary of Key Question 1c (Effectiveness of CAS versus medical therapy on long-term outcomes)

The strength of evidence is graded as insufficient because of a lack of RCTs. One available nonrandomized comparative study rated quality-B that showed a significantly decreased risk of any stroke or death with CAS and medical therapy over medical therapy alone. Although this study attempted to balance the observed clinical characteristics in the two intervention groups by applying a propensity score-matched analysis, this study did not report ipsilateral stroke.

#### CAS and medical therapy versus CEA and medical therapy (Key Question 1d)

Data for the comparison of CAS with CEA for efficacy and safety endpoints (Key Questions 1–3) were contributed by three RCTs and 10 nonrandomized comparative studies. In the following section, the design characteristics of these 13 studies are described in detail (Table 7). The results of these studies are then presented according to which key question is addressed by each study.

Table 7 Summary characteristics of studies comparing CAS versus CEA

Study, Yr | Percent carotid stenosis | Description of ‘asymptomatic’ status | N subjects (followup) | Primary outcome | Periprocedural events (safety)
RCT
CREST81,82, 83 | ≥ 60% on DSA ≥ 70% on DUS ≥ 80% on CTA or MRA (if stenosis on DUS was 50-69%) | No symptoms Remotely symptomatic (>6 months) Recent symptoms in a different territory | 1181 (4yr) | Any periprocedural stroke, MI, or death or postprocedural ipsilateral stroke | Any stroke MI Any stroke, MI, or death Any stroke or death
SAPPHIRE21,84 | ≥ 80% on DUS | No symptoms (no further specification) | 237 (3yr) | Any periprocedural stroke, MI, or death or postprocedural ipsilateral stroke | Any stroke, MI, or death
Brooks, 2004 85 | ≥ 80% on DSA | No symptoms | 85 (4yr) | Any stroke/TIA | Any stroke/TIA Cranial nerve palsy
NRCS
CaRESS,86,87 , prospective | ≥ 75% on DUS (confirmed by DSA when needed) | No symptoms remotely symptomatic (>6 months) | 269 (4yr) | Any stroke or death^*^ | Any stroke; Death; MI; Any stroke or death^*^ Any stroke or death, or MI
Marine, 2006^88^, retrospective | ≥ 70% on DUS (MRA, CTA, DSA in selected patients) | No symptoms (no further specification) | 238 (30d) | No long-term outcome data | Any stroke Death MI Any stroke or death Cranial nerve palsy Hematoma
Bosiers, 2005^78^, retrospective | ≥ 80% (no specification of diagnostic method) | No symptoms (no further specification) | 122986 (<30d) | No long-term outcome data | Any stroke or death
McPhee, 2007,^89^ retrospective^*^ | nd | No symptomatic stenosis diagnosis codes present on admission | 238389 (<30d) | No long-term outcome data | Any stroke Death MI
McPhee, 2008,^90^ retrospective^*^ | nd | No symptomatic stenosis diagnosis codes present on admission | 1667 (30 d) | No long-term outcome data | Any stroke Death
Sidawy, 2009^91^ retrospective^*^ | nd | “Asymptomatic” coding in the SVS-Vascular Registry | 8706 (<30 d) | No long-term outcome data | Any stroke TIA Death MI Any stroke or death or MI
Giacovelli, 2010,^92^ retrospective^*^ | nd | No symptomatic stenosis diagnosis codes present on admission | 79 (30 d) | No long-term outcome data | Any stroke Death Any stroke or death Cranial nerve palsy Bleeding
De Rango, 2011, prospective93 | >70% on angiography | No symptoms (no further specification) | 1518 (5 y) | Any periprocedural stroke or death or postprocedural ipsilateral stroke | Any stroke or death
Bangalore, 2010, International Registry94 | ≥70% on color-coded DUS or angiography | No history of TIA or stroke | 1672 (1.5 y) | Death or stroke | None
Lindstrom, 2012, Swedvasc Registry95 | nd | No symptoms within the previous 6 months | (30 d) | No long-term outcome data | Any stroke Death MI Any stroke or death Any stroke or death or MI

CTA = computed tomography angiography, DSA = digital subtraction angiography, DUS = duplex ultrasonography, d= days, MI, myocardial infarction, MRA = magnetic resonance angiography, NRCS = nonrandomized comparative study, RCT = randomized controlled trial, nd = not documented, TIA = transient ischemic attack, y = year.

* Administrative dataset

#### Study characteristics

##### Randomized controlled trials

The Carotid Revascularization Endarterectomy Versus Stenting Trial (CREST),81,82 the SAPPHIRE21,84 and the Brooks 2004 trial85 met inclusion criteria for the comparison of CAS with CEA. CREST and the SAPPHIRE trial enrolled both symptomatic and asymptomatic patients with randomization stratified according to symptomatic status. Therefore, the treatments were randomly assigned among asymptomatic subgroup.

Although outcome data were reported separately for the asymptomatic populations enrolled in these trials, no power analyses for the primary outcome in the asymptomatic patient subgroups were conducted. Therefore, this requires a cautious interpretation of the asymptomatic subgroup data. The SAPPHIRE trial originally used group sequential design and was subsequently analyzed as a noninferiority trial in the published papers.21,84 Given that only the asymptomatic subgroup data were of interest to this report, we extracted the number of events in each treatment group from original publications of the SAPPHIRE trial and from data available at the FDA Web site. We calculated the relevant risk estimates without taking into account the noninferiority threshold originally used in this trial.96

CREST is the largest RCT published to date and enrolled asymptomatic patients from 108 U.S. centers and nine centers in Canada during the years 2005–2008. CREST was designed as an equivalence trial but, this was analyzed as a noninferiority trial in the FDA submission and as a superiority trial in the published paper.97 However, since we considered only the data for the asymptomatic subgroup and we utilized the effect estimates from the published CREST data in our meta-analyses, we analyzed this study as a superiority trial. The SAPPHIRE trial enrolled asymptomatic patients from 29 U.S. centers during the years 2000–2002, and the Brooks 2004 trial enrolled 85 asymptomatic patients from a single U.S. center; a total of 1504 patients were randomized to either CAS (754 patients) or CEA (750 patients). In this trial, no cerebrovascular outcomes occurred in either intervention group.

###### Eligibility criteria and definition of asymptomatic carotid stenosis

CREST included asymptomatic patients with carotid stenosis diagnosed by the ICAVL or the ACR accredited ultrasound laboratories and determined by using the NASCET criteria. Patients were evaluated for clinical (e.g. no history of allergy to study medications) and anatomical (e.g. appropriate measurements of target vessel and lack of excessive tortuosity) suitability for either of the revascularization techniques. Those who were at high surgical risk (due to medical or anatomical conditions), previous severe stroke (confounding endpoint assessment), chronic or paroxysmal atrial fibrillation within the preceding 6 months or in need of anticoagulation therapy, MI within the previous 30 days, or unstable angina were excluded.

The SAPPHIRE trial also used the NASCET criteria for quantifying carotid stenosis, as measured by an ICAVL accredited vascular laboratory and required the presence of at least one of the following conditions conferring high surgical risk: clinically significant cardiac disease, severe pulmonary disease, contralateral carotid occlusion, contralateral laryngeal-nerve palsy, previous radical neck surgery or radiation therapy to the neck, recurrent stenosis after endarterectomy or age > 80 years. A patient was randomized only if all members of each participating center's team agreed that the patient was a suitable candidate for CEA or CAS. When team members disagreed, the patient was entered in a surgical or stenting registry according to the treating physicians' preference for treatment.

The Brooks 2004 trial included asymptomatic patients with an anticipated life expectancy of 5 years who were willing to complete treatment within 1 month of enrollment.

###### Interventions

In the CREST, both surgeons and interventionists had to have certification of technical competency. Certification was achieved by 477 surgeons (documenting more than 12 procedures annually and with adverse event rates < 3 percent in asymptomatic patients) and by 224 interventionists (after satisfactory evaluation of their endovascular experience, CAS results, and participation in hands-on and in a lead-in phase of training). The surgical technique involved the use of selective shunt in 53.6 percent and a patch in 68.5 percent of the cases. CEA was performed under general anesthesia in 87.5 percent of the cases. CAS involved the placement of the RX Acculink Carotid Stent System with the concomitant use of the RX Accunet® Embolic Protection device, whenever feasible (97.9 percent of the cases). Periprocedurally, the majority of patients treated with CAS (88 percent) received dual antiplatelet therapy (aspirin plus thienopyridines), with 99 percent of patients in the CAS group being covered by at least one antiplatelet agent; the continuation of antiplatelet therapy beyond 30 days was recommended to all patients. Patients treated with CEA were under single agent antiplatelet treatment (aspirin or thienopyridines) or combination of aspirin and extended-release dipyridamole. The majority of patients (96.9 percent) continued to receive these regimens for a year or more. Patients in both groups received the contemporary standard of care medical treatment, including treatment of hypertension and hyperlipidemia, as considered by the study authors.

In the SAPPHIRE trial, certification of surgeons and interventionists required compliance with the AHA criteria for acceptable rates of adverse events with CEA and incidence of periprocedural stroke or death with CAS of less than 6 percent, respectively. Surgeons had a median annual volume of 30 CEA (range of 15-to-100 procedures), performed according to their customary techniques. Interventionists had a lifetime experience of CAS with a median of 64 procedures (range of 20 to 700). The stent used was a self-expanding, nitinol stent (S.M.A.R.T® or PRECISE®, both by Cordis Corporation) with an emboli-protection device (ANGIOGUARD® or ANGIOGUARD™ XP, Cordis). There were many modifications to the device design during the course of the SAPPHIRE trial. Patients on both groups received aspirin at a daily dose of 81 or 325mg before intervention, and continued indefinitely. Patients on the CAS group received 75mg of clopidogrel starting 24 hours before the procedure and continuing for 2-to-4 weeks.

In the single-center RCT by Brooks 2004, CEA was performed by standard techniques under general anesthesia with electroencephalographic monitoring, with no further information on surgeons' technical competency. CAS was performed without the use of embolic protection devices and two types of stents were placed: Carotid WALLSTENT® Endoprosthesis (Boston Scientific Corporation/Medi-tech Division, Natick, MA) or Dynalink (Guidant Corp., Indianapolis, IN). The Brooks 2004 trial differed from the other RCTs in that patients on both groups received dual antiplatelet therapy (325mg aspirin and 75mg clopidogrel) before intervention, but no data were available regarding continuation of antiplatelet therapy postprocedurally.

###### Study outcomes

The primary efficacy endpoint evaluated in CREST and in the SAPPHIRE trial was the composite of any periprocedural stroke, MI, or death, or postprocedural ipsilateral stroke within 4 years of randomization.

In CREST, neurologic evaluation was performed at baseline, 18 to 54 hours after the procedure, 1 month afterwards, and then every 6 months, which included the TIA-Stroke Questionnaire.98 Study committees unaware of the treatment assignments adjudicated stroke and MI outcomes. MI was defined by a creatine kinase MB or troponin level that was twice the upper limit of the normal range or higher according to the center's laboratory, in addition to either chest pain or symptoms consistent with ischemia or ECG evidence of ischemia.

Outcome data from the SAPPHIRE trial were reported in two publications, including periprocedural and 1-year outcomes in the first paper and 3-year results in the second paper.21,84 Followup visits were scheduled at 30 days, 6 and 12 months, and annually thereafter. Neurologic evaluation included the National Institutes of Health Stroke Scale, which was assessed daily after the intervention until discharge and at all followup visits. Outcomes adjudication was by a committee composed of neurologists, surgeons, and cardiologists who were unaware of the treatment assignments.

The Brooks 2004 trial reported both periprocedural and long-term outcomes, evaluated by a neurologist at specified intervals.

###### Baseline characteristics

Baseline characteristics are shown in Appendix E, Table 10. The average ages of patients ranged from 66.6 to 72.6 years, and the proportion of males ranged from 63.8 to 67.5 percent. In terms of cardiovascular risk factors, the majority of patients had hypertension (85.1 to 91.0 percent); or hyperlipidemia (76.9 to 91.1 percent), except in the Brooks 2004 trial hyperlipidemia was present in only 21 percent. Diabetes mellitus was present in less than a third of patients. A minority of patients in CREST and the SAPPHIRE trial had current smoking habit, but a vast majority of patients in the Brooks 2004 trial were smokers (whether current or ex-smokers was not defined). In CREST, about 50 percent of patients had overt coronary artery disease in contrast to the SAPPHIRE trial in which about 81 percent had coronary artery disease. Regarding the severity of carotid stenosis, 91 percent of patients in CREST had a stenosis ≥ 70 percent whereas in the SAPPHIRE and Brooks 2004 trials, all patients had ≥ 80 percent stenosis. In the SAPPHIRE trial, 22.4 percent followed a prior CEA, and a small proportion of patients (3.4 percent) had a history of prior cerebrovascular event; no respective data were provided by the other two studies. Additionally, 25 percent of the patients enrolled in the SAPPHIRE trial had contralateral carotid artery occlusion.

###### Study quality

The CREST trial was rated quality-A. The SAPPHIRE and the Brooks 2004 trials were rated quality-B. Most of the methodological aspects evaluated as quality items (Appendix E, Table 11) were met by CREST and the SAPPHIRE trials, with the exception of “blinding” of patients and analyses accounting for center effects. The SAPPHIRE trial was rated as quality-B due to protocol violations observed in the conduct of this study and differences in reported results between published and unpublished reports. The SAPPHIRE trial was initially planned to demonstrate equivalence of two interventions, with a RCT sample size of 600–900 patients (symptomatic and asymptomatic). However, the trial was terminated early due to the slow pace of enrollment after a total of 334 patients (237 asymptomatic). Thus, data from the asymptomatic population were provided only by a subgroup with a small sample size. An additional potential limitation of the SAPPHIRE trial stems from its enrollment scheme requiring consensus of the team regarding the suitability of patients for revascularization; thus, the majority of patients enrolled were not finally randomized but were entered into the stenting registry. The Brooks 2004 trial was rated quality-B mainly due to its small sample size.

##### Nonrandomized comparative studies

Of the 10 eligible nonrandomized comparative studies (predominantly quality-C studies), four studies included clinical datasets,78,86-88,93 and six studies analyzed administrative and registry datasets.89-92,94,95 One study was prospective (quality-B) and the remaining six were retrospective in design (quality-C). The prospective trial, the Carotid Revascularization Using Endarterectomy or Stenting Systems (CaRESS) study, was a multicenter, nonrandomized study that included 269 patients.86,87 The second prospective study included 1,518 patients with asymptomatic carotid stenosis from a single high-volume vascular center.93 Of the retrospective studies, two small single-center studies (nonrandomized comparative studies /clinical) evaluated asymptomatic patients treated with CAS (152 patients) and CEA (175 patients).78,88 The remaining six studies (nonrandomized comparative studies /administrative) reported retrospective analyses of hospital discharge data from administrative databases or registry datasets. Two studies utilized data from the National Inpatient Sample database from different calendar years,89,90 one study analyzed data from the Society for Vascular Surgery – Vascular Registry (SVS-VR),91 one study collected data from New York and California state databases and applied a propensity score-matched analysis,92 and two recent studies examined registry data (REACH registry94 and Swedvasc registry95) In total, 30,275 patients treated with CAS and 346,177 patients treated with CEA were analyzed in these datasets.

###### Eligibility criteria and definition of asymptomatic carotid stenosis

About half of the patients enrolled in CaRESS were considered as high-risk for surgery, as defined by presence of contralateral stenosis, restenosis, advanced heart failure, prior coronary artery bypass grafting, age >80 years, or chronic obstructive pulmonary disease. Patients receiving CAS in the Marine 2006 study were also of high-surgical risk (mainly due to medical high-risk according to the SAPPHIRE criteria, restenosis, anatomically high lesion, or prior radiation to the neck). The Bosiers 2005 study included patients with > 80 percent stenosis, of which 26 percent were considered to be high-risk according to similar criteria. The studies on administrative datasets used the “International Classification of Diseases Ninth Revision, Clinical Modification” (ICD-9CM) procedural codes for CEA and CAS, and classified patients as asymptomatic when their discharge diagnoses did not include any codes indicative of stroke or TIA. In the SVS-VR, patients were analyzed as asymptomatic according to the data reported by providers of CAS and CEA through web-based entries. In these administrative datasets, no information on the degree of carotid stenosis was provided.

###### Interventions

In the CaRESS study, interventionists were required to have successfully deployed at least 20 carotid stents with < 6 percent rate of periprocedural stroke or death. The Carotid WALLSTENT® Monorail® Endoprosthesis was used with concurrent embolic protection device (GuardWire Plus, Medtronic USA, Inc.). Patients were on dual antiplatelet therapy for one month and were maintained on a daily dose of 325mg of aspirin indefinitely. Surgeons in CaRESS had an annual average of at least 50 CEA procedures and with a rate of stroke and death of less than 6 percent. Patients undergoing CEA were placed on aspirin, but no further data were provided regarding the surgical technique. In the Marine 2006 study, the surgeons met the ≤three percent stroke or death rate criterion as set by the AHA,15 whereas for many of the participating interventionists the study cases represented their first experience. The stents used included WALLSTENT® or Acculink in the majority of cases, with the use of the FilterWire EX™ embolic protection device in more than 90 percent of the patients. Selective shunt was used in 46 percent, patch in 82 percent, and general anesthesia in 36 percent of the CEAs. In the SVS-VR, it was reported that 95 percent of the CAS interventions were conducted with an embolic protection device. No data regarding the revascularization techniques or medical treatment were provided in the remaining studies.

###### Study outcomes

Long-term efficacy outcomes over a followup period of 4 years were reported only by the CaRESS study. The remaining studies evaluated only periprocedural adverse events; three studies evaluated periprocedural outcomes over a 30-day followup period,86-88,91 whereas the remaining three studies89,90,92 included adverse events occurring within the in-hospital postprocedural period. Neurologic outcome ascertainment by a certified neurologist was reported by two studies. 86-88 For studies utilizing administrative datasets,89,90,92 outcome ascertainment was based solely on information from hospital discharge data.

###### Baseline characteristics

Baseline characteristics of the populations included in the nonrandomized comparative studies of CAS with CEA are shown in Appendix E, Table 10. The average ages of patients ranged from 69.6 to 72.0 years, and the proportion of males ranged from 56.9 to 63.4 percent. In terms of cardiovascular risk factors, the majority of patients were suffering from hypertension (65.7 to 91.4 percent); hyperlipidemia was reported only by two studies and was present in 64.0 to 75.3 percent of patients. Data on frequency of diabetes mellitus were reported by most of the studies showing the presence of diabetes in about a quarter of the patient populations. Data on the severity of stenosis were provided only by three studies, which included predominantly 86,87 or exclusively78,88 patients with an advanced >70 percent stenosis. The concomitant presence of coronary artery disease displayed variability in this sample of studies, with proportions of patients ranging from 11.0 to 74.2 percent; however, the exact definitions of the diagnosis of coronary artery disease were commonly unavailable.

###### Study quality

The CaRESS study was a prospective nonrandomized comparative study with pre-specified endpoints and followup protocol. This study was rated quality-B. The remaining clinical and administrative nonrandomized comparative studies were retrospective in design and were all rated quality-C. An important limitation in the administrative nonrandomized comparative studies was that the apparent asymptomatic baseline status of the patients and the outcome ascertainment were informed only by hospital discharge data or registry data entries and were not subjected to case-by-case adjudication. Two studies attempted to analytically control for observed confounders through propensity score-matched analyses.92,94

### Key Question 1d (Long-term outcomes 12 months or greater)

#### Ipsilateral stroke (including any stroke within 30 days)

##### RCTs of CAS versus CEA

Two RCTs reported data on ipsilateral stroke (Figure 10). CREST reported it as a composite of any periprocedural stroke (within 30 days) or postprocedural (> 30 days) stroke ipsilateral to the treated carotid artery at 4-year followup. The SAPPHIRE trial defined it as ipsilateral stroke at 1 year, for which the data were obtained from the FDA Web site. At 4-year followup in CREST, CAS had a statistically nonsignificant increase in the occurrence of ipsilateral stroke as compared with CEA (HR = 1.86, 95% CI = 0.95, 3.66). The SAPPHIRE trial reported similar rates of ipsilateral stroke between CAS and CEA (5.2% vs. 5.3%). However, neither study was powered to detect differences in ipsilateral stroke among subgroups of asymptomatic carotid stenosis. The failure to find statistically significant differences does not rule out the possibility that real differences exist between interventions. We observed a discrepancy between the reported number of events in the CEA arm of the SAPPHIRE trial between different tables of available data on the FDA Web site, we performed a sensitivity analysis by considering an alternative number of observed events in the CEA arm (six instead of eight ipsilateral stroke).97

Figure 10 Forest plot of ipsilateral stroke in RCTs of CAS versus CEA

CAS = carotid angioplasty and stenting; CEA = carotid endarterectomy; CI = confidence interval; RR = risk ratio

RR < 1 favors CAS over CEA

Figure 10 is a graphical plot of ipsilateral stroke in two randomized controlled trials that compared carotid artery stenting (CAS) versus carotid endarterectomy (CEA) and reported on ipsilateral stroke. The Carotid Revascularization Endarterectomy Versus Stenting Trial [CREST] and the Stenting and Angioplasty with Protection in Patients at High Risk for Endarterectomy [SAPPHIRE] trials) trial reported it at 4-year and at 1-year followup. The graph provides relative risk (RR) and associated confidence intervals (CI) as well as a column each for number of events in both CEA and medical therapy groups from each study. Individual results are as follows: CREST 2010, RR = 1.82 (0.94, 3.55); SAPPHIRE 2008, RR = 0.77 (0.28, 2.15).

##### Nonrandomized comparative studies of CAS versus CEA

The nonrandomized comparative studies did not report this outcome.

#### Any stroke (including any death within 30 days)

##### RCTs of CAS versus CEA

Both CREST and the SAPPHIRE trial reported data on any stroke. In a meta-analysis, there was no significant difference in the risk of any stroke between CAS and CEA (summary RR = 1.37, 95% CI = 1.00, 1.87). There was no statistical heterogeneity (I^2^ = 0.0%, P=0.58).

##### Nonrandomized comparative studies of CAS versus CEA

One nonrandomized comparative study (CaRESS) reported data on any stroke (RR = 1.34, 95% CI = 0.51, 3.47). No significant difference between CAS and CEA was found (P=0.65) in an additional time-to-event analysis for the outcome of stroke-free survival by the study (unpublished data shared by the CaRESS study authors).

#### Any stroke or TIA

##### RCTs of CAS versus CEA

One RCT, the Brooks 2004 trial, examined the outcome of any stroke or TIA but reported zero events for both treatment groups; thus, no estimate of efficacy of CAS versus CEA could be deducted from this study.

##### Nonrandomized comparative studies of CAS versus CEA

One study examining REACH registry data reported no significant difference between CAS and CEA (HR = 0.91, 95% CI = 0.46, 1.80).

#### Any stroke or death

##### RCTs of CAS versus CEA

CREST reported a nonsignificantly increased risk of any stroke or death in CAS as compared with CEA (adjusted HR = 1.86; 95% CI 0.95, 3.66). The SAPPHIRE trial did not report data for this outcome.

##### Nonrandomized comparative studies of CAS versus CEA

In addition, one randomized comparative study reported data on any stroke or death. The CaRESS study reported no statistically significant difference between CAS and CEA (RR = 1.26, 95% CI = 0.77, 2.05). One study examining REACH registry data reported lower risk in the CAS group, but no significant difference between groups (HR = 0.67, 95% CI = 0.43, 1.05).

#### Any stroke or MI, or death

##### Nonrandomized comparative studies of CAS versus CEA

This composite outcome was examined in one nonrandomized comparative study (CaRESS) but no statistically significant effect of CAS versus CEA was found (RR = 1.18; 95% CI = 0.72, 1.91). One study examining REACH registry data reported significantly lower risk of this composite outcome with CAS, as compared with CEA (HR = 0.62, 95% CI = 0.42, 0.91).

#### Death

##### RCTs of CAS versus CEA

There was a nonsignificantly decreased risk of death with CAS as compared with CEA in the SAPPHIRE trial (RR = 0.47, 95% CI = 0.18, 1.20). The CREST trial did not report data for this outcome.

##### Nonrandomized comparative studies of CAS versus CEA

In contrast to the RCT data, the CaRESS study reported an increased risk that did not reach statistical significance (RR = 1.36, 95% CI = 0.78, 2.35). In an additional time-to-event analysis for the outcome of survival by the CaRESS study, no significant difference between CAS and CEA was found (P=0.38) (unpublished data shared by the study authors).

#### Composite endpoint including ipsilateral stroke

##### Any periprocedural stroke, MI, or death or postprocedural ipsilateral stroke

###### RCTs of CAS versus CEA

This composite outcome represented the primary outcome of CREST and the SAPPHIRE trial over the 4-year and 3-year followup, respectively. Neither trial found a statistically significant difference between CAS and CEA. The observed point estimates showed different directions of effects (unfavorable for CAS in CREST and favorable in the SAPPHIRE trial) and their confidence interval in each study was wide (Figure 11). However, neither trial was powered to detect differences in the primary outcome among subgroups of asymptomatic carotid stenosis. Therefore, the failure to find statistically significant differences does not rule out the possibility that real differences exist between interventions.

Figure 11 Forest plot of any periprocedural stroke, MI or death or postprocedural ipsilateral stroke in RCTs of CAS versus CEA

CAS = carotid angioplasty and stenting; CEA = carotid endarterectomy; CI = confidence interval; RR = risk ratio

RR < 1 favors CAS over CEA

Figure 11 is a meta-graph of analysis of any periprocedural stroke, MI or death or postprocedural ipsilateral stroke in two randomized controlled trials that compared carotid artery stenting (CAS) versus carotid endarterectomy (CEA) and reported on ipsilateral stroke. The Carotid Revascularization Endarterectomy Versus Stenting Trial [CREST] and the Stenting and Angioplasty with Protection in Patients at High Risk for Endarterectomy [SAPPHIRE] trials) trial reported it at 4-year and at 3-year followup. The graph provides relative risk (RR) and associated confidence intervals (CI) as well as a column each for number of events in both CEA and medical therapy groups from each study. Individual results are as follows: CREST 2010, RR = 1.14 (0.68, 1.90); SAPPHIRE 2008, RR = 0.73 (0.47, 1.14).

###### Nonrandomized comparative studies of CAS versus CEA

The nonrandomized comparative studies did not report this outcome.

##### Any periprocedural stroke or death or postprocedural ipsilateral stroke

###### RCTs of CAS versus CEA

CREST and the SAPPHIRE trial reported data on the composite outcome of any periprocedural stroke, or death and postprocedural ipsilateral stroke. CREST reported a statistically nonsignificantly increased HR (adjusted for age, sex, and symptom status) with CAS as compared with CEA for this composite outcome (HR = 1.86, 95% CI = 0.95, 3.66). The SAPPHIRE trial reported a statistically nonsignificantly decreased risk of this composite outcome with CAS as compared with CEA (RR = 0.54, 95% CI =0.28, 1.02). As shown in Figure 12, the observed point estimates in these two studies were extremely discordant.

Figure 12 Forest plot of any periprocedural stroke or death or postprocedural ipsilateral stroke in RCTs of CAS versus CEA

CAS = carotid angioplasty and stenting; CEA = carotid endarterectomy; CI = confidence interval; RR = risk ratio

RR < 1 favors CAS over CEA

Figure 12 is a forest plot of analysis of any periprocedural stroke or death or postprocedural ipsilateral stroke ipsilateral stroke in two randomized controlled trials that compared carotid artery stenting (CAS) versus carotid endarterectomy (CEA) and reported on ipsilateral stroke. The Carotid Revascularization Endarterectomy Versus Stenting Trial [CREST] and the Stenting and Angioplasty with Protection in Patients at High Risk for Endarterectomy [SAPPHIRE] trials) trial reported it at 4-year and at 1-year followup. The graph provides relative risk (RR) and associated confidence intervals (CI) as well as a column each for number of events in both CEA and medical therapy groups from each study. Individual results are as follows: CREST 2010, RR = 1.82 (0.94, 3.55); SAPPHIRE 2008, RR = 0.54 (0.24, 1.02).

###### Nonrandomized comparative studies of CAS versus CEA

The nonrandomized comparative studies did not report this outcome.

#### Summary of Key Question 1d (Effectiveness of CAS versus CEA on long-term outcomes)

There were no statistically significant differences between the two interventional modalities. The strength of evidence is graded as insufficient because two RCTs (one quality-A and one quality-B) evaluated very different patient groups. For each of the outcome assessed (ipsilateral stroke and composite endpoint), the observed point estimates were in opposite directions across trials (as evidenced in forest plots). Furthermore, there was clinical heterogeneity and selective reporting of outcomes of interest. In one trial (SAPPHIRE), there were differences in reporting between the published paper and unpublished data on the FDA Web site. The nonrandomized comparative studies did not report long-term data for the outcome of ipsilateral stroke.

### Summary incidence rate by treatment group

The summary incidence rate of medical therapy alone was 1.59 percent per year of followup quality-A and -B studies. In a subgroup analysis, the summary incidence rate of ipsilateral stroke was significantly decreased in recent studies (recruitment closure year between 2000 and 2010) as compared with studies in the previous years, recruitment closure year before 2000 (1.1 versus 2.3 percent per year of followup).

Five RCTs (the VA study, ACAS, ACST, CREST, and the SAPPHIRE trial) contributed to the incidence rate meta-analysis of CEA and medical therapy arm. We estimated that the summary incidence rate of ipsilateral stroke in patients with asymptomatic carotid stenosis who had CEA and medical therapy was 1.42 percent per year of followup. In a subgroup analysis of patients who had CEA and medical therapy, the summary incidence rate of ipsilateral stroke was significantly decreased in recent studies (recruitment closure year between 2000 and 2010) as compared with studies in the previous years, recruitment closure year before 2000 (1.3 versus 1.6 percent per year of followup). From two RCTs (CREST and SAPPHIRE) that reported long-term data, we estimated that the individual incidence rates of ipsilateral stroke in patients with asymptomatic carotid stenosis who had CAS with medical therapy. It is important to note that both studies recruited patients after 2000 (Table 8).

Table 8 Summary incidence rates of ipsilateral stroke by treatment groups

| Medical therapy alone | CEA with medical therapy | CAS with medical therapy
Number studies | 26 | 5 | 2
Number subjects | 7,210 | 3,303 | 711
Study quality | 20 A or B | 4 A; 1B^*^ | 1A; 1B^**^
Summary incidence rate of ipsilateral stroke (% per year of followup) | 1.59 (95% CI = 1.21, 2.09) | 1.42 (95% CI = 0.70, 2.91), | CREST: 1.61 (95% CI =1.03, 2.40) SAPPHIRE: 5.12 (95% CI = 1.88, 11.16)
Recent studies (recruitment closure since 2000) | 1.13 (95% CI = 0.95, 1.34) | 1.30 (95% CI =0.40, 4.50) | CREST: 1.61 (95% CI =1.03, 2.40) SAPPHIRE: 5.12 (95% CI = 1.88, 11.16)
Older studies (recruitment closure before 2000) | 2.38 (95% CI = 1.87, 2.85) | 1.60 (95% CI = 1.20, 2.10) | Not applicable

Detailed descriptions of medical therapy alone studies are provided in Table 1.

* CEA treatment groups from the following five RCTs: Veterans Affairs Cooperative (VA) Study; Asymptomatic Carotid Atherosclerosis Study (ACAS); Asymptomatic Carotid Surgery Trial (ACST); Carotid Revascularization Endarterectomy Versus Stenting Trial (CREST) trial; and Stenting and Angioplasty with Protection in Patients at High Risk for Endarterectomy (SAPPHIRE)

** CAS treatment groups from the following two RCTs: CREST and SAPPHIRE

N = number; CEA = carotid endarterectomy; CAS = carotid angioplasty and stenting

## Key Question 2 (Subgroups and treatment effect)

### CEA and medical therapy versus medical therapy alone

Two quality-A rated RCTs (ACAS and the ACST) reported subgroup-specific data. The VA trial did not report subgroup-specific data. The outcomes evaluated for subgroups include ipsilateral stroke (including perioperative stroke or death) in ACAS, nonperioperative carotid territory stroke in the 5-year followup, and any stroke in the 10-year followup of ACST. Since these trials reported subgroup-specific data for three different outcomes, we did not conduct meta-analysis of these data subgroups, but presented data on at least four comparable subgroups as forest plots in Figure 13. No specific subgroup analyses were reported in nonrandomized comparative studies.

Figure 13 Forest plot of ipsilateral stroke, and any stroke by subgroups^*^ * ACAS 1995 evaluates relative risk of ipsilateral stroke by subgroups; ACST 2004 evaluates relative risk of carotid territory stroke by subgroups; and ACST 2010 evaluates incidence rates of any stroke. Published paper of ACST 2010 estimates annual rates by subgroups, while the figure here evaluates incidence rates. comparing CEA and medical therapy with medical therapy alone

Relative risk or incidence rate ratio <1 favors CEA over medical therapy.

Figure 13 is a forest plot presenting data from at least four comparable subgroups (gender, age, degree of stenosis, and symptomatic or asymptomatic status) for the outcomes of ipsilateral strokes (including perioperative stroke or death) from the ACAS 1995 trial, carotid territory stroke from the ACST-1 2004 trial, and any stroke in the ACST-1 2010 trial of carotid endarterectomy (CEA) versus medical therapy. The graph plots the relative risk of these outcomes in the ACAS 1995 and ACST 2004 trials, and the incidence rate ratio in the ACST 2010 trial and their associated confidence intervals. Only men who had CEA and medical therapy had significantly lower risk in ACAS 1995. In ACST 2004 men, age < 65 years, stenosis < 80 percent, and symptomatic contralateral stenosis who had CEA and medical therapy compared with medical therapy alone had significantly lower risk. In ACST 2010, all subgroups who had CEA and medical therapy or medical therapy alone had lower risk of any stroke.

#### Demographic and other preoperative (baseline) features of studied patients in RCTs

##### Age: Subgroup of patients ≥ 65 years

Both ACAS and ACST stratified their analyses on the basis of age categories (Figure 9). ACAS reported that patients aged < 68 years with asymptomatic carotid stenosis in the CEA group had a significantly decreased risk of ipsilateral stroke compared to the medical therapy group, but those ≥ 68 years of age had no difference between the two treatment groups. ACST reported that patients < 65 and 65–74 years of age had a significantly decreased risk of nonperioperative carotid territory stroke at 5 years and a significantly decreased risk of any stroke at 10 years with CEA as compared with medical therapy alone, but patients ≥ 75 years of age had no significant difference between the two treatment groups.

##### Age: Subgroup of patients ≥ 80 years

There was no evidence available in the evaluated studies, as they did not specifically report on the subgroup of patients ≥ 80 years of age with asymptomatic carotid stenosis. In fact, ACAS excluded these patients. In the 10-year followup of ACST, both men and women < 75 years of age had significantly decreased annual rates of any stroke in the CEA group as compared with the medical therapy group. Similar reduction was not reported for the subgroup of men or women ≥ 75 years of age.

##### Sex

The VA trial included only men and the remaining two RCTs included a higher proportion of men than women. In ACAS, men in the CEA group had lower numbers of observed ipsilateral strokes than men in the medical therapy group after 2.7 years of followup; no similar reduction was reported for women. ACAS reported that during a projected 5-year followup, according to Kaplan–Meier analysis, men had a significantly decreased risk of ipsilateral stroke (including perioperative stroke or death) in the CEA group than in the medical therapy group. During the 5-and 10-year followups of ACST, both men and women received greater benefits with CEA than with medical therapy for the outcome of nonperioperative carotid territory stroke or any stroke, respectively.

##### Clinical and anatomic features of carotid artery stenosis

In ACAS, patients with prior symptoms due to contralateral stenosis or prior contralateral CEA had a reduced risk of ipsilateral stroke (including perioperative stroke or death) in the CEA group as compared with the medical therapy group on the basis of 5-year projected estimates from the Kaplan-Meier analysis. However, at the median 2.7-year followup in ACAS, there were more events in the CEA group than in the medical therapy group among patients who had prior symptoms due to contralateral stenosis or prior contralateral CEA. In ACST at the 10-year followup, patients with prior symptoms due to contralateral stenosis or prior contralateral CEA had no difference between the two treatment groups. Regardless of the degree of stenosis, in ACST, patients in the CEA group had a significantly decreased risk of carotid territory stroke at 5 years as compared with patients in the medical therapy group, while in the 10-year followup, only a subgroup of patients with 70–89 percent stenosis had significantly decreased annual rates of any stroke in the CEA group as compared with the medical therapy group.

##### Average or high risk for CEA due to comorbid diseases

All three RCTs excluded the majority of patients who were believed to be at high risk for CEA owing to associated medical illnesses. ACST reported a subgroup analysis of a small number of patients who had diabetes or ischemic heart disease at study entry; there was no difference in the risk of nonperioperative ipsilateral stroke between the CEA and medical treatment groups.

##### Concurrent and postoperative treatments

Only the 10-year followup of ACST evaluated any nonperioperative stroke stratified by concurrent use of medications (antihypertensive therapy, antithrombotic therapy, and lipid-lowering therapy) at study entry. An additional analysis was conducted for the ipsilateral stroke outcome stratified by concurrent use of medications at the time of outcome assessment. Less than 55 percent of patients were using antihypertensive therapy, and approximately 11 percent were using lipid-lowering therapies, at randomization. The medical therapy usage continued to increase in the later years of followup in both the CEA and medical therapy groups, with up to 89 percent of patients using antihypertensive therapy and 82 percent using lipid-lowering therapy. Regardless of the usage of antihypertensive or lipid-lowering therapy, as compared with the medical therapy group, the CEA group had a significantly decreased risk of carotid artery territory stroke at 5 years and significantly decreased annual rates of any stroke at 10 years.

##### Length of followup

Overall estimates of ipsilateral stroke or any stroke after CEA decreased with followup, but estimates of death did not change regardless of whether 5- or 10-year data were used from ACST.

##### Methodological quality of studies

All three RCTs were rated quality A.

#### Demographic and other preoperative (baseline) features of studied patients in comparative studies of CEA versus medical therapy

Four nonrandomized comparative studies included patients with an average age of ≥ 65 years that reported heterogeneous and inconclusive results for the comparison of CEA and medical therapy with medical therapy alone. Two retrospective nonrandomized comparative studies evaluated patients with > 75 percent stenosis and one study reported 2.5 percent perioperative events in the CEA group, while the other reported no events in both groups. No specific subgroup analyses were conducted in these studies.

All nonrandomized comparative studies were rated either quality-B or -C, had considerable heterogeneity and reported variable results in outcomes of ipsilateral stroke, any stroke, and the combined endpoint of any stroke or death.

### CAS and medical therapy versus medical therapy alone

The noncomparative study (Sherif 2005) included patients with > 70 percent asymptomatic carotid stenosis and reported data on long-term adverse clinical outcomes. This study did not report outcomes of ipsilateral stroke outcomes. This study did not evaluate any subgroups as predictors of outcomes. In addition, the Bosiers 2005 study did not report any subgroup analyses.

### CAS versus CEA

Two trials (CREST and SAPPHIRE) reported some subgroup-specific data. No specific subgroup analyses were reported in nonrandomized comparative studies.

#### Demographic and other baseline features of studied patients in RCTs

##### Age: Subgroup of patients ≥ 65 years

The average age of patients enrolled in RCTs ranged from 66.6 to 72.6 years; among patients included in nonrandomized comparative studies, age ranged from 69.6 to 72.0 years. However, no study provided data for the age subgroups < 65 years or ≥ 65 years; thus, we could not evaluate whether the treatment effect of CAS as compared with CEA was different between these patient populations. Given that the majority of patients included in the analyzed studies were aged ≥ 65 years, the results of these studies can be considered applicable to those ≥ 65 years of age with asymptomatic carotid artery stenosis.

##### Age: Subgroup of patients ≥ 80 years

No subgroup analysis by patient age was reported in asymptomatic carotid stenosis.

##### Sex

CREST reported data stratified by sex in asymptomatic patients, on the basis of a prespecified secondary analysis.83 Both men and women had nonsignificantly increased hazard ratios for the primary composite endpoint, stroke, and stroke or death with CAS as compared with CEA.

##### Clinical, and anatomic features of CAS

The SAPPHIRE trial included only patients with > 80 percent carotid stenosis and found no significant differences between CAS and CEA for ipsilateral or any stroke, death, or the composite primary endpoint.

##### Average or high risk for CEA due to comorbid diseases

All patients included in the SAPPHIRE trial were considered to be at high risk for adverse events on the basis of the clinical and anatomic features specified in the trial eligibility criteria. No significant differences between CAS and CEA were found for ipsilateral or any stroke, death, or the composite primary endpoint.

##### Types of stents used and use of embolic protection devices

Data on the specific type of stents and embolic protection devices were provided by three RCTs (CREST, SAPPHIRE, and Brooks 2004) that examined long-term clinical outcomes. CREST and the SAPPHIRE trial, each used different types of stents. The trials did not report subgroup data according to the specific type of stents used.

All trials had a high rate of embolic protection device utilization (> 90 percent). The Brooks 2004 study did not use embolic protection devices. The majority of patients in trials that reported long-term outcomes (CREST and SAPPHIRE) underwent CAS with embolic protection devices. These trials did not report subgroup-specific data for the patients that did not receive such devices. Therefore, the impact of the use of embolic protection devices on the treatment effect of CAS could not be evaluated.

##### Concurrent and postoperative treatments

CREST and the SAPPHIRE trial employed similar medical treatment for perioperative management (dual antiplatelet therapy for the CAS group and single antiplatelet therapy for the CEA group) and long-term management of patients, and thus, no relevant data are available to examine the impact of various medical treatments on clinical outcomes.

##### Length of followup

The SAPPHIRE trial reported data in two different publications, with 1-year followup data given in 2004 and 3-year followup data in 2008. The 1-year data showed a significant 53 percent reduction in the risk of the primary outcome with CAS over CEA (RR = 0.47, 95% CI = 0.25, 0.89); this effect was no longer significant at 3 years (RR = 0.73, 95% CI = 0.47, 1.14).

##### Methodological quality of studies

Data for the long-term efficacy of CAS as compared with CEA were reported in one quality-A RCT (CREST) and one quality-B RCT (SAPPHIRE). The observed point estimates for outcomes were in opposite directions. However, there were no significant differences in the risk of ipsilateral stroke or composite primary endpoint between the two intervention groups.

#### Demographic and other baseline features of studied patients in nonrandomized comparisons of CAS versus CEA

One nonrandomized comparative study (CaRESS) reported data on the specific type of stents and the use of embolic protection devices. The impact of the use of embolic protection devices on the treatment effect of CAS could not be evaluated because no subgroup-specific data for the patients that did not receive such devices were provided. This study was rated as quality-B and reported no significant difference in the risk of stroke or composite outcomes between the two intervention groups.

#### Summary of Key Question 2 (Subgroups and treatment effect for all treatment comparisons)

For the comparisons of CEA and medical therapy with medical therapy alone, two quality-A RCTs (ACAS and ACST) reported subgroup-specific data. The strength of evidence is graded as insufficient, because these trials reported subgroup-specific data for three outcomes that cannot be combined. The outcomes evaluated for subgroups were ipsilateral stroke, including perioperative stroke or death, in the ACAS, nonperioperative carotid territory stroke in the 5-year followup of ACST, and any territory stroke in the 10-year followup of ACST. In addition, there was insufficient information on certain subgroups. The nonrandomized comparative studies comparing of CEA and medical therapy with medical therapy alone provided insufficient information on the subgroup-specific data.

The strength of evidence is graded as insufficient on the basis of a lack of RCT data for the comparison of CAS and medical therapy with medical therapy alone. No specific subgroup analyses were reported in the nonrandomized comparative studies.

The strength of evidence is graded as insufficient for the comparison of CAS with CEA because there was insufficient information or only one of the three RCTs (CREST, SAPPHIRE, and Brooks 2004) reported data for subgroups of interest. No subgroup analyses were reported by one nonrandomized comparative study that reported long-term outcomes.

## Key Question 3 (Outcomes occurring within 30 days)

### CEA and medical therapy versus medical therapy alone

Two RCTs (VA and ACAS) and three nonrandomized comparative studies reported data on adverse events and complications within 30 days. All studies were conducted in the early 1990s except for one more recent retrospective nonrandomized comparative study by Bosiers 2005, which retrospectively reviewed their 2003 data.78

Patients randomly assigned to CEA underwent surgery within 10 days in the VA trial or within 14 days in ACAS. The periprocedural period for the medically treated patients was defined as 30 days and 42 days after randomization in the VA trial and ACAS, respectively. We did not include ACST in evaluating this outcome, as the definition of perioperative morbidity and mortality in the ACST medical therapy group differed considerably from the definitions used in the other two trials. ACST compared the rate of periprocedural events between the immediate CEA group and the deferred CEA group after they were operated on.

The retrospective nonrandomized comparative study, Bosiers 2005, included all patients with > 80 percent asymptomatic carotid stenosis. In general, there was incomplete reporting of baseline and surgical characteristics in this study (Appendix E, Table 2). The study also included in the analysis 25 percent of patients who were at high risk for CEA.

### Any periprocedural stroke

#### RCTs of CEA versus medical therapy

Two RCTs (VA and ACAS) reported a significantly higher risk of any stroke during periprocedural period in the CEA compared with the corresponding followup period in the medical therapy alone (summary RR = 5.94, 95% CI = 2.06, 17.12). There was no statistical heterogeneity (I^2^ = 0.0%, P=0.91).

#### Nonrandomized comparative studies of CEA versus medical therapy

Two nonrandomized comparative studies reported periprocedural events occurring in CEA, but there were no events reported during corresponding followup period in the medical therapy.

### Periprocedural death

#### RCTs of CEA versus medical therapy

Two RCTs (VA and ACAS) reported a nonsignificantly higher risk of death during periprocedural period with CEA than during the corresponding followup period in the medical therapy (summary RR = 3.68, 95% CI = 0.77, 17.72). There was no statistical heterogeneity (I^2^ = 0.0%, P=0.82).

#### Nonrandomized comparative studies of CEA versus medical therapy

The nonrandomized comparative studies did not report this outcome.

### Periprocedural MI

#### RCTs of CEA versus medical therapy

Two RCTs reported a nonsignificantly higher risk of MI during periprocedural period with CEA than during the corresponding followup period in the medical therapy alone (summary RR = 8.39, 95% CI = 1.00, 70.33). There was no statistical heterogeneity (I^2^ = 0.0%, P=0.39).

#### Nonrandomized comparative studies of CEA versus medical therapy

The nonrandomized comparative studies did not report this outcome.

### Periprocedural composite outcomes

#### Stroke or death during the periprocedural period or within 30 days followup

##### RCTs of CEA versus medical therapy

The risk of stroke or death with or without MI during the periprocedural period was significantly higher with CEA than with medical therapy alone, according to data from the analysis of two trials (VA and ACAS) (Figures 14–15). The estimates of outcomes during periprocedural period did not change considerably with or without the addition of stroke or death attributable to the selective use of arteriography in ACAS.

Figure 14 Meta-analysis of stroke and death during 30-day period in RCTs of CEA versus medical therapy

CEA = carotid endarterectomy; Med = medical therapy; RR = risk ratio

RR >1 favors medical therapy alone over CEA and medical therapy

Figure 14 is a meta-graph of random effects analysis of the outcomes of periprocedural stroke and death in two randomized controlled trials that compared carotid endarterectomy (CEA) and medical therapy versus medical therapy alone (Veteran's Affairs Cooperative Study 1993 and the Asymptomatic Carotid Atherosclerosis Study 1995) with the selective use of arteriography in the ACAS trial. The graph provides relative risk (RR) and associated confidence intervals (CI) as well as a column each for number of events in both CEA and medical therapy groups from each study. Outcomes during periprocedural time period did not change considerably with or without the addition of stroke or death due to the selective use of arteriography in the ACAS trial. Summary results are as follows: RR = 5.35, 95% CI = 2.24, 12.78, with no heterogeneity (I² = 0.0%, P = 0.924) Individual results are as follows: VA 1993, RR = 4.42, 95% CI = 1.26, 15.44; ACAS 1995, RR = 6.40, 95% CI = 1.90, 21.55.

Figure 15 Meta-analysis of stroke, MI, and death during 30-day period in RCTs CEA versus medical therapy

CEA = carotid endarterectomy; Med = medical therapy; RR = risk ratio

RR >1 favors medical therapy alone over CEA and medical therapy

Figure 15 is a meta-graph of random effects analysis of the outcomes of periprocedural stroke and death in two randomized controlled trials that compared carotid endarterectomy (CEA) and medical therapy versus medical therapy alone (Veteran's Affairs Cooperative Study 1993 and the Asymptomatic Carotid Atherosclerosis Study 1995) with the selective use of arteriography in the ACAS trial. The graph provides relative risk (RR) and associated confidence intervals (CI) as well as a column each for number of events in both CEA and medical therapy groups from each study. Outcomes during periprocedural time period did not change considerably with or without the addition of stroke or death due to the selective use of arteriography in the ACAS trial. Summary results are as follows: RR = 6.14, 95% CI = 2.60, 14.52, with no heterogeneity (I² = 0.0%, P = 0.924) Individual results are as follows: VA 1993, RR = 5.89, 95% CI = 1.74, 19.93; ACAS 1995, RR = 6.40, 95% CI = 1.90, 21.55.

##### Nonrandomized comparative studies of CEA versus medical therapy

In contrast to the RCTs, three nonrandomized comparative studies (Bosiers 2005, Mayo 1992, and Hertzer 1986) reported periprocedural events occurring in the CEA groups, whereas no events occurred during the corresponding followup period in the medical therapy groups.

### Periprocedural cranial nerve palsy

#### RCTs of CEA versus medical therapy

One RCT reported cranial nerve palsy after CEA but no such events occurred during the corresponding followup period in the medical therapy.

#### Nonrandomized comparative studies of CEA versus medical therapy

One nonrandomized comparative study reported cranial nerve palsy after CEA but no such events during the corresponding followup period in the medical therapy.

### Periprocedural bleeding complications

#### RCTs of CEA versus medical therapy

No trial reported major bleeding events.

#### Nonrandomized comparative studies of CEA versus medical therapy

One nonrandomized comparative study reported no major bleeding events in the CEA group.

#### Summary of Key Question 3 (CEA versus medical therapy: outcomes within 30 days)

The strength of evidence is graded as moderate, but may not translate to contemporary clinical practice for periprocedural outcomes of RCTs of CEA and medical therapy as compared with medical therapy alone. At randomization, patients with asymptomatic carotid stenosis were not receiving what is currently considered the best medical therapy or contemporary postoperative medical management. Two quality-A RCTs in patients with asymptomatic carotid stenosis showed an increase in the risk of adverse events including any stroke, death, or MI with CEA and medical therapy over medical therapy alone.

### CAS and medical therapy versus medical therapy alone

A single nonrandomized comparative study (Bosiers 2005) provided data for the endpoint of any stroke or death during the periprocedural 30-day period and reported no significant differences between the CAS and medical therapy compared with medical therapy alone (Appendix E, Table 9).

#### Any stroke or death

The risk of stroke or death was reported during the periprocedural 30-day period between the CAS group (1.7 percent) and the medical therapy group (0.0 percent).

#### Summary

The strength of evidence is graded as insufficient based on lack of RCTs.

### CAS and medical therapy versus CEA and medical therapy

Data for the comparison of periprocedural adverse events of CAS and CEA were provided by all available 10 studies (three RCTs and seven nonrandomized comparative studies). Periprocedural outcomes were considered all outcomes occurring within 30 days from the intervention or in the case of the administrative nonrandomized comparative studies, all outcomes occurring within the period of hospitalization. Detailed descriptions are summarized in Appendix E, Tables 17–22.

#### Any periprocedural stroke

##### RCTs of CAS versus CEA

All RCTs reported this outcome (Figure 16). CREST reported a statistically nonsignificant increase in the occurrence of any periprocedural stroke in CAS as compared with CEA (adjusted HR = 1.88, 95% CI = 0.79, 4.42). Similar results were reported in the SAPPHIRE trial, with a statistically nonsignificant increase in the risk of any periprocedural stroke (RR = 1.54, 95% CI = 0.44, 5.31) or ipsilateral stroke (RR = 1.71, 95% CI = 0.42, 6.99) with CAS as compared with CEA. . No cerebrovascular events occurred in the Brooks 2004 trial.

Figure 16 Forest plot of any periprocedural stroke in RCTs of CAS versus CEA

CAS = carotid angioplasty and stenting; CEA = carotid endarterectomy; CI = confidence interval; RR = risk ratio

RR < 1 favors CAS over CEA

Figure 16 is a meta-graph of random effects analysis of periprocedural stroke in two randomized controlled trials (RCTs) of carotid angioplasty and stenting (CAS) versus carotid endarterectomy (CEA) [(Carotid Revascularization Endarterectomy versus Stenting Trial [CREST] 2010 and Stenting and Angioplasty with Protection in Patients at High Risk for Endarterectomy (SAPPHIRE) 2008]. The graph provides relative risk (RR) and associated confidence intervals (CI) as well as a column each for number of events in both CAS and CEA groups from each study. Individual results are as follows: CREST 2010, RR = 1.85, 95% CI = 0.79, 4.34; SAPPHIRE 2008, RR = 1.54, 95% CI = 0.87, 3.52.

##### Nonrandomized comparative studies of CAS versus CEA

Six nonrandomized comparative studies reported this outcome. The meta-analysis of two nonrandomized comparative studies with clinical datasets (one quality-B and one quality-C) showed a nonsignificant decrease in the risk of periprocedural stroke with CAS, thus favoring CAS over CEA (summary RR = 0.55, 95% CI = 0.11, 2.67), without statistical heterogeneity (I^2^ = 0.0%, P=0.95) (Figure 17).

Figure 17 Meta-analysis of any periprocedural stroke in nonrandomized comparative studies of CAS versus CEA

CAS = carotid angioplasty and stenting; CEA = carotid endarterectomy; CI = confidence interval; RR = risk ratio

RR < 1 favors CAS over CEA

Figure 17 is a meta-graph of random effects analysis of periprocedural stroke in two randomized controlled studies of carotid artery stenting (CAS) versus carotid endarterectomy (CEA) treated patients (the Carotid Revascularization Using Endarterectomy or Stenting Systems trial [CaRESS] and Marine 2006). The graph provides relative risk (RR) and associated confidence intervals as well as a column each for number of events in both carotid angioplasty and stenting (CAS) and carotid endarterectomy (CEA) groups from each study. Meta-analysis of two nonrandomized comparative studies showed no significant decrease in the risk of periprocedural stroke favoring CAS over CEA (summary RR = 0.55, 95% CI = 0.11, 2.67), with no evidence of statistical heterogeneity (P=0.95). Individual results are as follows: CaRESS, RR = 0.57, 95% CI = 0.06, 5.43; Marine 2006, RR = 0.52, 95% CI = 0.05, 4.92).

On the contrary, meta-analysis of the four nonrandomized comparative studies with administrative data (all quality-C) resulted in a significant summary estimate showing a 71 percent increased risk for periprocedural stroke with CAS compared with CEA (summary RR = 1.71, 95% CI = 1.34, 2.26), with statistically significant heterogeneity (I^2^=75%; P=0.007) (Figure 18).

Figure 18 Meta-analysis of any periprocedural stroke in nonrandomized comparative studies (administrative datasets) of CAS versus CEA

CAS = carotid angioplasty and stenting; CEA = carotid endarterectomy; CI = confidence interval; RR = risk ratio

RR < 1 favors CAS over CEA

Figure 18 is a meta-graph of random effects analysis of periprocedural stroke in four nonrandomized comparative studies (NRCS) of carotid angioplasty and stenting (CAS) versus carotid endarterectomy (CEA) treated patients (McPhee 2007, McPhee 2008, Sidawy 2009, Giacovelli 2010). The graph provides relative risk (RR) and associated confidence intervals (CI) as well as a column each for events in the CAS and CEA groups from each study. Summary results from meta-analysis are as follows: RR = 1.71, 95% CI = 1.34, 2.26 with evidence of statistically significant heterogeneity (I² = 75%, P=0.007). Individual results are as follows: McPhee 2007, RR = 2.09, 95% CI = 1.82, 2.40; McPhee 2008, RR = 1.82, 95% CI = 1.55, 2.13; Sidawy 2009, RR = 1.65, 95% CI = 0.78, 3.51; Giacovelli 2010 = RR = 1.17, 95% CI = 0.86, 1.59; Giacovelli 2010, RR = 1.71, 95% CI = 1.34, 2.16.

Although these nonrandomized comparisons included much larger sample sizes than the RCTs, these studies are observational in nature and are prone to biases, such as confounding by indication. The single study (Giacovelli 2010) that attempted to address observed confounders with propensity score-matched analyses showed no significant increase in the risk of stroke (RR = 1.17, 95% CI = 0.86, 1.59).

#### Periprocedural death

##### RCTs of CAS versus CEA

Two RCTs (CREST and SAPPHIRE) reported this outcome. In CREST, there was no periprocedural death in the two treatment groups. The SAPPHIRE trial reported a statistically nonsignificant increase in the risk of periprocedural death between CAS and CEA (RR = 2.05, 95% CI = 0.18, 22.3), but the wide CI indicates great uncertainty.

##### Nonrandomized comparative studies of CAS versus CEA

Five nonrandomized comparative reported this outcome. Single nonrandomized comparative study (Marine 2006) based on clinical dataset reported no statistical difference between CAS and CEA (RR = 1.56, 95% CI = 0.10, 24.6). In a meta-analysis of four nonrandomized comparative studies based on administrative datasets, there was a significant increase in the risk of periprocedural death with CAS (summary RR = 1.43, 95% CI = 1.20, 1.71), without statistical heterogeneity (I^2^ = 0.0%, P=0.44) (Figure 19).

Figure 19 Meta-analysis of periprocedural death in nonrandomized comparative studies (administrative datasets) of CAS versus CEA

CAS = carotid angioplasty and stenting; CEA = carotid endarterectomy; CI = confidence interval; RR = risk ratio

RR < 1 favors CAS over CEA

Figure 19 is a meta-graph of random effects analysis of periprocedural stroke in four nonrandomized comparative studies (NRCS) of carotid angioplasty and stenting (CAS) versus carotid endarterectomy (CEA) treated patients (McPhee 2007, McPhee 2008, Sidawy 2009, Giacovelli 2010). The graph provides relative risk (RR) and associated confidence intervals (CI) as well as a column each for number of events in both CAS and CEA groups from each study. Summary results from meta-analysis are as follows: RR = 1.43, 95% CI = 1.20, 1.71 with no evidence of significant heterogeneity (P=0.44). Individual results are as follows: McPhee 2007, RR = 1.29, 95% CI = 0.98, 1.70; McPhee 2008, RR = 1.49, 95% CI = 1.15, 1.94; Sidawy 2009, RR = 2.86, 95% CI = 1.12, 7.26; Giacovelli 2010, RR = 1.41, 95% CI = 0.76, 2.62.

#### Periprocedural MI

##### RCTs of CAS versus CEA

Two RCTs (CREST and SAPPHIRE) reported nonsignificant reductions in the risk of periprocedural MI, favoring CAS over CEA (Figure 20).

Figure 20 Forest plot of periprocedural MI in RCTs of CAS versus CEA

CAS = carotid angioplasty and stenting; CEA = carotid endarterectomy; CI = confidence interval; RR = risk ratio

RR < 1 favors CAS over CEA

Figure 20 is a meta-graph of random effects analysis of periprocedural MI in two randomized controlled studies of carotid artery stenting (CAS) versus carotid endarterectomy (CEA) treated patients in the CREST and the SAPPHIRE trial. The graph provides relative risk (RR) and associated confidence intervals as well as a column each for number of events in both carotid angioplasty and stenting (CAS) and carotid endarterectomy (CEA) groups from each study. Individual results are as follows: CREST, RR = 0.53, 95% CI = 0.21, 1.32; SAPPHIRE 2008, RR = 0.38, 95% CI = 0.10, 1.41).

##### Nonrandomized comparative studies of CAS versus CEA

Four nonrandomized comparative studies reported this outcome. In a meta-analysis of two nonrandomized comparative studies based on clinical data (one quality-B and one quality-C), there was a nonsignificant decrease in the risk of MI with CAS compared with CEA (summary RR = 0.57, 95% CI = 0.09, 3.70), without statistical heterogeneity (I^2^ = 0.0%, P=0.67) (Figure 21).

Figure 21 Meta-analysis of periprocedural MI in nonrandomized comparative studies of CAS versus CEA

CAS = carotid angioplasty and stenting; CEA = carotid endarterectomy; CI = confidence interval; RR = risk ratio

RR < 1 favors CAS over CEA

Figure 21 is a meta-graph of random effects analysis of periprocedural MI in two clinical nonrandomized comparative studies (NRCS) of carotid angioplasty and stenting (CAS) versus carotid endarterectomy (CEA) [the Carotid Revascularization Using Endarterectomy or Stenting Systems trial (CaRESS) and Marine 2006]. The graph provides relative risk (RR) and associated confidence intervals (CI) as well as a column each for number of events in both CAS and CEA groups from each study. Meta-analysis found a non-significant decrease in the risk of MI with CAS (summary RR = 0.57, 95% CI = 0.09, 3.70), with no evidence of significant heterogeneity (P=0.67). Individual results are as follows: CaRESS 2005, RR = 0.34, 95% CI = 0.02, 7.05; Marine 2006, RR= 0.78, 95% CI = 0.07, 8.48.

Data from two available quality-C rated studies based on administrative data were not synthesized due to variability in the outcome rates. The estimate of the larger study reported a statistically significant 18 percent increased risk of MI in CAS compared with CEA (RR = 1.18, 95% CI = 1.04, 1.34). The smaller study reported a nonsignificantly increased risk of MI with CAS over CEA (RR = 2.36, 95% CI = 0.82, 6.75).

#### Periprocedural composite outcome of any stroke, MI, or death

##### RCTs of CAS versus CEA

Two RCTs (CREST and SAPPHIRE) examined this periprocedural composite endpoint. CREST reported no difference in the risk of this composite outcome between CAS and CEA (adjusted HR = 1.02, 95% CI = 0.55, 1.86). According to the reported events in the published paper of the SAPPHIRE trial, there was a nonsignificant decrease in the risk of the composite outcome with CAS compared with CEA (RR = 0.51, 95% CI = 0.19, 1.32).21 We observed some inconsistencies in the numbers of reported events for this outcome between the published paper and the data available from the FDA.

##### Nonrandomized comparative studies of CAS versus CEA

Among two nonrandomized comparative studies, the CaRESS study reported a nonsignificantly decreased risk of this composite endpoint with CAS compared with CEA (RR = 0.34, 95% CI = 0.03, 2.92). The second nonrandomized comparative study based on administrative data for this outcome showed opposing results, a statistically significant increased risk with CAS over CEA (RR = 2.33, 95% CI = 1.32, 4.10).

#### Periprocedural composite outcome of any stroke or death

##### RCTs of CAS versus CEA

Two RCTs (CREST and SAPPHIRE) examined this periprocedural composite endpoint. CREST reported a nonsignificant increase in the risk of this composite outcome with CAS as compared with CEA (adjusted HR = 1.88, 95% CI 0.79, 4.42). On the basis of the reported numbers of events in the FDA report of the SAPPHIRE trial, a nonsignificant increase in the risk of the composite outcome with CAS as compared with CEA was estimated (RR = 1.44, 95% CI = 0.47, 4.40).

##### Nonrandomized comparative studies of CAS versus CEA

Five nonrandomized comparative studies examined this periprocedural composite endpoint in a total of 2,014 patients with asymptomatic carotid stenosis. In a meta-analysis of four nonrandomized comparative studies based on clinical data, there was no significant difference between CAS and CEA (summary RR = 1.30, 95% CI = 0.69, 2.45), and there was no statistical heterogeneity (I^2^=0.0%, P = 0.87) (Figure 22).

Figure 22 Meta-analysis of any periprocedural stroke or death in nonrandomized comparative studies of CAS versus CEA

CAS = carotid angioplasty and stenting; CEA = carotid endarterectomy; CI = confidence interval; RR = risk ratio

RR < 1 favors CAS over CEA

Figure 22 is a meta-graph of random effects analysis of the periprocedural composite outcome of any stroke or death in three nonrandomized comparative studies (NCRS) [CaRESS 2005, prospective; Marine 2006, and Bossiers 2005, both retrospective] of carotid angioplasty stenting (CAS) versus carotid artery endarterectomy (CEA). Meta-analysis found no significant difference between CAS and CEA (summary RR = 0.86, 95% CI = 0.24, 3.07), with no evidence of significant heterogeneity (P = 0.91). Individual results are as follows: CaRESS 2005, RR= 0.57, 95% CI = 0.06, 5.43; Marine 2006, RR = 1.04, 95% CI = 0.18, 6.10; Bossiers 2005, RR = 1.05, 95% CI = 0.04, 24.79.

#### Periprocedural cranial nerve palsy

##### RCTs of CAS versus CEA

In a meta-analysis of CREST and the Brooks 2004 trial, there was a statistically significant reduction in the risk of cranial nerve palsy with CAS over CEA (summary RR = 0.06, 95% CI = 0.01, 0.31), and there was no statistical heterogeneity (I^2^=0.0%, P = 0.48) (Figure 23).

Figure 23 Meta-analysis of cranial nerve palsy in RCTs of CAS versus CEA

CAS = carotid angioplasty and stenting; CEA = carotid endarterectomy; CI = confidence interval; RR = risk ratio

RR < 1 favors CAS over CEA

Figure 23 is a meta-graph of random effects analysis of the periprocedural cranial nerve palsy in two randomized controlled trials of carotid angioplasty stenting (CAS) versus carotid artery endarterectomy (CEA). Meta-analysis found statistically significant difference in favor of CAS over CEA (summary RR = 0.06, 95% CI = 01, 0.31), with no evidence of significant heterogeneity (I2, P = 0.478). Individual results are as follows: CREST 2010, RR= 0.04, 95% CI = 0.01, 0.29; Brooks 2004, RR = 0.14, 95% CI = 0.01, 2.62.

##### Nonrandomized comparative studies of CAS versus CEA

Two nonrandomized comparative studies that examined cranial nerve palsy did not report significant reductions with CAS.

#### Periprocedural bleeding complications

##### RCTs of CAS versus CEA

One RCT (CREST) showed no significant differences in the risk of hematoma or bleeding between CAS and CEA.

##### Nonrandomized comparative studies of CAS versus CEA

Two nonrandomized comparative studies showed no significant differences in the risk of hematoma or bleeding between CAS and CEA.

#### Summary of Key Question 3 (CAS versus CEA - outcomes within 30 days)

The strength of evidence is graded as insufficient because between-trial comparisons were not possible, as there was extreme clinical heterogeneity. In addition, clinical trial outcomes were in opposite directions (periprocedural stroke or death were nonsignificantly higher in the CAS, and periprocedural MI events were nonsignificantly higher in the CEA). There were differences between published and unpublished data in one RCT. One quality-A RCT and two quality-B RCTs showed no statistically significant differences in the risk of adverse events, including any periprocedural stroke, death, or MI (or combinations thereof), in patients undergoing CAS as compared with those undergoing CEA.

The results of nonrandomized comparative studies based on clinical datasets concurred with the results of RCTs. In contrast, the nonrandomized comparative studies based on administrative datasets showed a significantly greater risk of periprocedural stroke, death, or MI in the CAS than in the CEA.

## Applicability

The trials comparing CEA and medical therapy with medical therapy alone reported using standard medical therapy available at that period, but did not report the use of optimized therapy (e.g., specific target levels to manage comorbid conditions such as diabetes or hypertension or hyperlipidemia). Furthermore, at randomization, patients with asymptomatic carotid stenosis were not receiving what is considered current best medical therapy, including the use of statins. Thus the medical therapy used in these trials may not reflect those that are used in contemporary clinical practice. All trials were conducted at tertiary centers and the results may not be generalizable to community settings.

There were insufficient data comparing CAS and medical therapy with medical therapy alone and therefore, the applicability was not assessed. At least one of the trials of CAS and medical therapy compared with CEA and medical therapy included patients for all the subgroups of interest. The patient selection process applied in the SAPPHIRE trial, in which almost half of potentially eligible patients were not randomized but rather were included in a stenting registry, poses significant limitations in assessing the applicability of the study results. Patient-selection issues were also reported in CREST prolonging the enrollment phase, in which eligible patients were enrolled into one of several stent registries. Both trials were conducted at tertiary medical centers, thus the results may not be generalizable to community settings.