# References

1 Roger VL, Go AS, Lloyd-Jones DM, et al. Heart disease and stroke statistics--2012 update: a report from the American Heart Association. Circulation. Jan. 3. 2012;125(1):e2-e220. [pmid: 22179539].
2 de WM, Greving JP, de Jong AW, et al. Prevalence of asymptomatic carotid artery stenosis according to age and sex: systematic review and metaregression analysis. Stroke. Apr. 2009;40(4):1105-13. [pmid: 19246704].
3 Wolff T, Guirguis-Blake J, Miller T GM, et al. Screening for Carotid Artery Stenosis: An Update of the Evidence for the U.S. Preventive Services Task Force. Ann Intern Med. Dec. 18. 2007;147(12):860-70. [pmid: 18087057].
4 Kartchner MM, McRae LP. Noninvasive evaluation and management of the “asymptomatic” carotid bruit. Surgery. Dec. 1977;82(6):840-47. [pmid: 929374].
5 Thompson JE, Patman RD, Talkington CM. Asymptomatic carotid bruit: long term outcome of patients having endarterectomy compared with unoperated controls. Annals of Surgery. Sep. 1978;188(3):308-16. [pmid: 686896].
6 Aronson L, Landefeld CS. Examining Older People for Carotid Bruits. J Gen Intern Med. Feb. 1998;13(2):140-41. [pmid: 9502377].
7 Sonecha TN, Delis KT, Henein MY. Predictive value of asymptomatic cervical bruit for carotid artery disease in coronary artery surgery revisited. Int J Cardiol. Feb. 15. 2006;107(2):225-29. [pmid: 16412801].
8 Muto PM, Welch HJ, Mackey WC, et al. Evaluation of carotid artery stenosis: is duplex ultrasonography sufficient?. J Vasc Surg. Jul. 1996;24(1):17-22. [pmid: 8691519].
9 Ferguson GG, Eliasziw M, Barr HW, et al. The North American Symptomatic Carotid Endarterectomy Trial : surgical results in 1415 patients. Stroke. Sep. 1999;30(9):1751-58. [pmid: 10471419].
10 Randomised trial of endarterectomy for recently symptomatic carotid stenosis: final results of the MRC European Carotid Surgery Trial (ECST). Lancet. May. 9. 1998;351(9113):1379-87. [pmid: 9593407].
11 Rothwell PM, Gibson RJ, Slattery J, et al. Equivalence of measurements of carotid stenosis. A comparison of three methods on 1001 angiograms. European Carotid Surgery Trialists' Collaborative Group. Stroke. Dec. 1994;25(12):2435-39. [pmid: 7974586].
12 Rothwell PM. Carotid stenting: more risky than endarterectomy and often no better than medical treatment alone. Lancet. Mar. 20. 2010;375(9719):957-59. [pmid: 20304225].
13 Abbott AL. Medical (nonsurgical) intervention alone is now best for prevention of stroke associated with asymptomatic severe carotid stenosis: results of a systematic review and analysis. Stroke. Oct. 2009;40(10):e573-e583. [pmid: 19696421].
14 Makris GC, Lavida A, Nicolaides AN, et al. The effect of statins on carotid plaque morphology: a LDL-associated action or one more pleiotropic effect of statins?. Atherosclerosis. Nov. 2010;213(1):8-20. [pmid: 20494361].
15 Goldstein LB, Bushnell CD, Adams RJ, et al. Guidelines for the Primary Prevention of Stroke A Guideline for Healthcare Professionals From the American Heart Association/American Stroke Association. Stroke. 2010. Dec. 6. [pmid: 21127304].
16 Chambers BR, Donnan GA. Carotid endarterectomy for asymptomatic carotid stenosis. Cochrane Database of Systematic Reviews. 2005;(4). CD001923. [pmid: 16235289].
17 Brott TG, Halperin JL, Abbara S, et al. ASA/ACCF/AHA/AANN/AANS/ACR/ASNR/CNS/SAIP/SCAI/SIR/SNIS/SVM/SVS guideline on the management of patients with extracranial carotid and vertebral artery disease: a report of the American College of Cardiology Foundation/American Heart Association Task Force on Practice Guidelines, and the American Stroke Association, American Association of Neuroscience Nurses, American Association of Neurological Surgeons, American College of Radiology, American Society of Neuroradiology, Congress of Neurological Surgeons, Society of Atherosclerosis Imaging and Prevention, Society for Cardiovascular Angiography and Interventions, Society of Interventional Radiology, Society of NeuroInterventional Surgery, Society for Vascular Medicine, and Society for Vascular Surgery. Circulation. Jul. 2011;124. [pmid: 21282504].
18 Decision Memo for Percutaneous Transluminal Angiolasty (PTA) of the Carotid Artery Concurrent with Stenting (CAG-00085R7). 2010. Available at: PM:None.
19 Rothwell PM, Slattery J, Warlow CP. Clinical and angiographic predictors of stroke and death from carotid endarterectomy: systematic review. BMJ. Dec. 13. 1997;315(7122):1571-77. [pmid: 9437274].
20 Sundt TM, Sandok BA, Whisnant JP. Carotid endarterectomy. Complications and preoperative assessment of risk. Mayo Clin Proc. Jun. 1975;50(6):301-06. [pmid: 1127994].
21 Yadav JS, Wholey MH, Kuntz RE, et al. Protected carotid-artery stenting versus endarterectomy in high-risk patients. New England Journal of Medicine. Oct. 7. 2004;351(15):1493-501. [pmid: 15470212].
22 Methods Guide for Effectiveness and Comparative Effectiveness Review. Agency for Healthcare Research and Quality. 2011. Available at: http://effectivehealthcare.ahrq.gov/.
23 Ulm K. A simple method to calculate the confidence interval of a standardized mortality ratio (SMR). Am J Epidemiol. Feb. 1990;131(2):373-75. [pmid: 2296988].
24 Bagos P, Nikolopoulos GK. Mixed-Effects Poisson Regression Models for Meta-Analysis of Follow-Up Studies with Constant or Varying Durations. Int J Biostat. 2009;5(1). Article 21. PM:None.
25 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. Sep. 1986;7(3):177-88. [pmid: 3802833].
26 Thompson SG, Higgins JP. How should meta-regression analyses be undertaken and interpreted?. Stat Med. Jun. 15. 2002;21(11):1559-73. [pmid: 12111920].
27 Higgins JP, Thompson SG. Controlling the risk of spurious findings from meta-regression. Stat Med. Jun. 15. 2004;23(11):1663-82. [pmid: 15160401].
28 Endarterectomy for asymptomatic carotid artery stenosis. Executive Committee for the Asymptomatic Carotid Atherosclerosis Study. JAMA. May. 10. 1995;273(18):1421-28. [pmid: 7723155].
29 Risk of stroke in the distribution of an asymptomatic carotid artery. The European Carotid Surgery Trialists Collaborative Group. Lancet. Jan. 28. 1995;345(8944):209-12. [pmid: 7823712].
30 Halliday A, Mansfield A, Marro J, et al. Prevention of disabling and fatal strokes by successful carotid endarterectomy in patients without recent neurological symptoms: randomised controlled trial. Lancet. May. 8. 2004;363(9420):1491-502. [pmid: 15135594].
31 Halliday A, Harrison M, Hayter E, et al. 10-year stroke prevention after successful carotid endarterectomy for asymptomatic stenosis (ACST-1): a multicentre randomised trial. Lancet. Sep. 25. 2010;376(9746):1074-84. [pmid: 20870099].
32 Hobson RW, Weiss DG, Fields WS, et al. Efficacy of carotid endarterectomy for asymptomatic carotid stenosis. The Veterans Affairs Cooperative Study Group. New England Journal of Medicine. Jan. 28. 1993;328(4):221-27. [pmid: 8418401].
33 Anderson DC, Kappelle LJ, Eliasziw M, et al. Occurrence of hemispheric and retinal ischemia in atrial fibrillation compared with carotid stenosis. Stroke. Aug. 2002;33(8):1963-67. [pmid: 12154246].
34 Inzitari D, Eliasziw M, Gates P, et al. The causes and risk of stroke in patients with asymptomatic internal-carotid-artery stenosis. North American Symptomatic Carotid Endarterectomy Trial Collaborators. New England Journal of Medicine. Jun. 8. 2000;342(23):1693-700. [pmid: 10841871].
35 AbuRahma AF, Cook CC, Metz MJ, et al. Natural history of carotid artery stenosis contralateral to endarterectomy: results from two randomized prospective trials. Journal of Vascular Surgery. Dec. 2003;38(6):1154-61. [pmid: 14681599].
36 Abbott AL, Chambers BR, Stork JL, et al. Embolic signals and prediction of ipsilateral stroke or transient ischemic attack in asymptomatic carotid stenosis: a multicenter prospective cohort study. Stroke. Jun. 2005;36(6):1128-33. [pmid: 15879327].
37 AbuRahma AF, Metz MJ, Robinson PA. Natural history of > or =60% asymptomatic carotid stenosis in patients with contralateral carotid occlusion. Annals of Surgery. 2003;238(4):551-61. [pmid: 14530726].
38 Ballotta E, Da GG, Meneghetti G, et al. Progression of atherosclerosis in asymptomatic carotid arteries after contralateral endarterectomy: a 10-year prospective study. Journal of Vascular Surgery. Mar. 2007;45(3):516-22. [pmid: 17275244].
39 Bogousslavsky J, Despland PA, Regli F. Asymptomatic tight stenosis of the internal carotid artery: long-term prognosis. Neurology. Jun. 1986;36(6):861-63. [pmid: 3703297].
40 Goessens BM, Visseren FL, Kappelle LJ, et al. Asymptomatic carotid artery stenosis and the risk of new vascular events in patients with manifest arterial disease: the SMART study. Stroke. May. 2007;38(5):1470-75. [pmid: 17363718].
41 Gronholdt ML, Nordestgaard BG, Schroeder TV, et al. Ultrasonic echolucent carotid plaques predict future strokes. Circulation. Jul. 3. 2001;104(1):68-73. [pmid: 11435340].
42 Gur AY, Bova I, Bornstein NM. Is impaired cerebral vasomotor reactivity a predictive factor of stroke in asymptomatic patients?. Stroke. Dec. 1996;27(12):2188-90. [pmid: 8969778].
43 Johnson JM, Kennelly MM, DeCesare D, et al. Natural history of asymptomatic carotid plaque. Archives of Surgery. Sep. 1985;120(9):1010-12. [pmid: 3896195].
44 Johnson BF, Verlato F, Bergelin RO, et al. Clinical outcome in patients with mild and moderate carotid artery stenosis. Journal of Vascular Surgery. Jan. 1995;21(1):120-26. [pmid: 7823350].
45 Levien LJ, Fritz VU, Lithgow-Jolly P. The natural history of asymptomatic carotid disease. A preliminary report. S Afr J Surg. Nov. 1984;22(4):249-53. [pmid: 6523303].
46 Liapis CD, Kakisis JD, Kostakis AG. Carotid stenosis: factors affecting symptomatology. Stroke. Dec. 1. 2001;32(12):2782-86. [pmid: 11739973].
47 Mackey AE, Abrahamowicz M, Langlois Y, et al. Outcome of asymptomatic patients with carotid disease. Asymptomatic Cervical Bruit Study Group. Neurology. Apr. 1997;48(4):896-903. [pmid: 9109874].
48 Mansour MA, Littooy FN, Watson WC, et al. Outcome of moderate carotid artery stenosis in patients who are asymptomatic. J Vasc Surg. Feb. 1999;29(2):217-25. [pmid: 9950980].
49 Markus HS, King A, Shipley M, et al. Asymptomatic embolisation for prediction of stroke in the Asymptomatic Carotid Emboli Study (ACES): a prospective observational study. Lancet Neurol. Jul. 2010;9(7):663-71. [pmid: 20554250].
50 Marquardt L, Geraghty OC, Mehta Z, et al. Low risk of ipsilateral stroke in patients with asymptomatic carotid stenosis on best medical treatment: a prospective, population-based study. Stroke. Jan. 2010;41(1):e11-e17. [pmid: 19926843].
51 Kakkos SK, Nicolaides A, Griffin M, et al. Factors associated with mortality in patients with asymptomatic carotid stenosis: results from the ACSRS Study. International Angiology. Sep. 2005;24(3):221-30. [pmid: 16158030].
52 Nicolaides AN, Kakkos SK, Griffin M, et al. Severity of asymptomatic carotid stenosis and risk of ipsilateral hemispheric ischaemic events: results from the ACSRS study. European Journal of Vascular & Endovascular Surgery. Sep. 2005;30(3):275-84. [pmid: 16130207].
53 Silvestrini M, Vernieri F, Pasqualetti P, et al. Impaired cerebral vasoreactivity and risk of stroke in patients with asymptomatic carotid artery stenosis. JAMA. Apr. 26. 2000;283(16):2122-27. [pmid: 10791504].
54 Spence JD, Tamayo A, Lownie SP, et al. Absence of microemboli on transcranial Doppler identifies low-risk patients with asymptomatic carotid stenosis. Stroke. Nov. 2005;36(11):2373-78. [pmid: 16224084].
55 Spence JD, Coates V, Li H, et al. Effects of intensive medical therapy on microemboli and cardiovascular risk in asymptomatic carotid stenosis. Archives of Neurology. Feb. 2010;67(2):180-86. [pmid: 20008646].
56 Takaya N, Yuan C, Chu B, et al. Association between carotid plaque characteristics and subsequent ischemic cerebrovascular events: a prospective assessment with MRI--initial results. Stroke. Mar. 2006;37(3):818-23. [pmid: 16469957].
57 Longstreth WT Jr., Shemanski L, Lefkowitz D, et al. Asymptomatic internal carotid artery stenosis defined by ultrasound and the risk of subsequent stroke in the elderly. The Cardiovascular Health Study. Stroke. Nov. 1998;29(11):2371-76. [pmid: 9804651].
58 Zhang C, Qu S, Li H, et al. Microembolic signals and carotid plaque characteristics in patients with asymptomatic carotid stenosis. Scand Cardiovasc J. 2009;43(5):345-51. [pmid: 19863395].
59 Results of a randomized controlled trial of carotid endarterectomy for asymptomatic carotid stenosis. Mayo Asymptomatic Carotid Endarterectomy Study Group. Mayo Clin Proc. Jun. 1992;67(6):513-18. [pmid: 1434877].
60 Carotid surgery versus medical therapy in asymptomatic carotid stenosis. The CASANOVA Study Group. Stroke. Oct. 1991;22(10):1229-35. [pmid: 1926232].
61 Aichner FT, Topakian R, Alberts MJ, et al. High cardiovascular event rates in patients with asymptomatic carotid stenosis: the REACH Registry. European Journal of Neurology. Aug. 2009;16(8):902-08. [pmid: 19473362].
62 Satiani B Jr., Porter RM. The influence of contralateral disease on the natural history of nonoperated significant carotid stenosis. Ann Vasc Surg. Jul. 1990;4(4):313-17. [pmid: 2364044].
63 Langsfeld M, Gray-Weale AC, Lusby RJ. The role of plaque morphology and diameter reduction in the development of new symptoms in asymptomatic carotid arteries. Journal of Vascular Surgery. Apr. 1989;9(4):548-57. [pmid: 2651727].
64 Satiani B, Chen TY, Shook L, et al. Contralateral disease progression after carotid endarterectomy. Surgery. Jul. 1993;114(1):46-51. [pmid: 8356526].
65 Takahashi W, Ohnuki T, Ide M, et al. Stroke risk of asymptomatic intra- and extracranial large-artery disease in apparently healthy adults. Cerebrovasc Dis. 2006;22(4):263-70. [pmid: 16788300].
66 Siebler M, Nachtmann A, Sitzer M, et al. Cerebral microembolism and the risk of ischemia in asymptomatic high-grade internal carotid artery stenosis. Stroke. Nov. 1995;26(11):2184-86. [pmid: 7482670].
67 Hennerici M, Hulsbomer HB, Hefter H, et al. Natural history of asymptomatic extracranial arterial disease. Results of a long-term prospective study. Brain. Jun. 1987;110(Pt 3):777-91. [pmid: 3580834].
68 Norris JW, Zhu CZ, Bornstein NM, et al. Vascular risks of asymptomatic carotid stenosis. Stroke. Dec. 1991;22(12):1485-90. [pmid: 1962321].
69 Bock RW, Gray-Weale AC, Mock PA, et al. The natural history of asymptomatic carotid artery disease. J Vasc Surg. Jan. 1993;17(1):160-69. [pmid: 8421333].
70 Ellis MR, Franks PJ, Cuming R, et al. Prevalence, progression and natural history of asymptomatic carotid stenosis: is there a place for carotid endarterectomy?. European Journal of Vascular Surgery. Mar. 1992;6(2):172-77. [pmid: 1572457].
71 Sabeti S, Schlager O, Exner M, et al. Progression of carotid stenosis detected by duplex ultrasonography predicts adverse outcomes in cardiovascular high-risk patients. Stroke. Nov. 2007;38(11):2887-94. [pmid: 17885257].
72 Dick P, Sherif C, Sabeti S, et al. Gender differences in outcome of conservatively treated patients with asymptomatic high grade carotid stenosis. Stroke. Jun. 2005;36(6):1178-83. [pmid: 15890998].
73 Greenland S, O'Rourke K. On the bias produced by quality scores in meta-analysis, and a hierarchical view of proposed solutions. Biostatistics. Dec. 2001;2(4):463-71. [pmid: 12933636].
74 Libman RB, Sacco RL, Shi T, et al. Outcome after carotid endarterectomy for asymptomatic carotid stenosis. Surgical Neurology. Jun. 1994;41(6):443-49. [pmid: 8059320].
75 Hertzer NR, Flanagan RA Jr., Beven EG, et al. Surgical versus nonoperative treatment of asymptomatic carotid stenosis. 290 patients documented by intravenous angiography. Annals of Surgery. Aug. 1986;204(2):163-71. [pmid: 3527089].
76 Poulias GE, Doundoulakis N, Skoutas B, et al. Carotid artery surgery and the principle of prophylaxis: recurrence in operated and nonoperated patients. Cardiovascular Surgery. Oct. 1994;2(5):586-91. [pmid: 7820518].
77 Caracci BF, Zukowski AJ, Hurley JJ, et al. Asymptomatic severe carotid stenosis. Journal of Vascular Surgery. Feb. 1989;9(2):361-66. [pmid: 2645445].
78 Bosiers M, Peeters P, Deloose K, et al. Selection of treatment for patients with carotid artery disease: medication, carotid endarterectomy, or carotid artery stenting. Vascular. Mar. 2005;13(2):92-97. [pmid: 15996363].
79 Ogata T, Yasaka M, Wakugawa Y, et al. Long-term results of medical and surgical therapy for Japanese patients with moderate carotid stenosis. J Stroke Cerebrovasc Dis. Jan. 2012;21(1):24-29. [pmid: 20851631].
80 Sherif C, Dick P, Sabeti S, et al. Neurological outcome of conservative versus endovascular treatment of patients with asymptomatic high-grade carotid artery stenosis: a propensity score-adjusted analysis. Journal of Endovascular Therapy: Official Journal of the International Society of Endovascular Specialists. Apr. 2005;12(2):145-55. [pmid: 15823061].
81 Brott TG, Hobson RW, Howard G, et al. Stenting versus endarterectomy for treatment of carotid-artery stenosis. New England Journal of Medicine. Jul. 1. 2010;363(1):11-23. [pmid: 20505173].
82 Silver FL, Mackey A, Clark WM, et al. Safety of stenting and endarterectomy by symptomatic status in the Carotid Revascularization Endarterectomy Versus Stenting Trial (CREST). Stroke. Mar. 2011;42(3):675-80. [pmid: 21307169].
83 Howard VJ, Lutsep HL, Mackey A, et al. Influence of sex on outcomes of stenting versus endarterectomy: a subgroup analysis of the Carotid Revascularization Endarterectomy versus Stenting Trial (CREST). Lancet Neurol. Jun. 2011;10(6):530-37. [pmid: 21550314].
84 Gurm HS, Yadav JS, Fayad P, et al. Long-term results of carotid stenting versus endarterectomy in high-risk patients. New England Journal of Medicine. Apr. 10. 2008;358(15):1572-79. [pmid: 18403765].
85 Brooks WH, McClure RR, Jones MR, et al. Carotid angioplasty and stenting versus carotid endarterectomy for treatment of asymptomatic carotid stenosis: a randomized trial in a community hospital. Neurosurgery. May. 2004;54(2):318-24. [pmid: 14744277].
86 CaRESS Steering Committee. Carotid Revascularization Using Endarterectomy or Stenting Systems (CaRESS) phase I clinical trial: 1-year results. Journal of Vascular Surgery. Aug. 2005;42(2):213-19. [pmid: 16102616].
87 Zarins CK, White RA, Diethrich EB, et al. Carotid revascularization using endarterectomy or stenting systems (CaRESS): 4-year outcomes. Journal of Endovascular Therapy: Official Journal of the International Society of Endovascular Specialists. Aug. 2009;16(4):397-409. [pmid: 19702339].
88 Marine LA, Rubin BG, Reddy R, et al. Treatment of asymptomatic carotid artery disease: similar early outcomes after carotid stenting for high-risk patients and endarterectomy for standard-risk patients. Journal of Vascular Surgery. May. 2006;43(5):953-58. [pmid: 16678689].
89 McPhee JT, Hill JS, Ciocca RG, et al. Carotid endarterectomy was performed with lower stroke and death rates than carotid artery stenting in the United States in 2003 and 2004. Journal of Vascular Surgery. Dec. 2007;46(6):1112-18. [pmid: 18154987].
90 McPhee JT, Schanzer A, Messina LM, et al. Carotid artery stenting has increased rates of postprocedure stroke, death, and resource utilization than does carotid endarterectomy in the United States, 2005. Journal of Vascular Surgery. Dec. 2008;48(6):1442-50. [pmid: 18829236].
91 Sidawy AN, Zwolak RM, White RA, et al. Risk-adjusted 30-day outcomes of carotid stenting and endarterectomy: results from the SVS Vascular Registry. Journal of Vascular Surgery. Jan. 2009;49(1):71-79. [pmid: 19028045].
92 Giacovelli JK, Egorova N, Dayal R, et al. Outcomes of carotid stenting compared with endarterectomy are equivalent in asymptomatic patients and inferior in symptomatic patients. J Vasc Surg. Oct. 2010;52(4):906-13. 913. [pmid: 20620010].
93 De RP, Parlani G, Verzini F, et al. Long-term prevention of stroke: a modern comparison of current carotid stenting and carotid endarterectomy. Journal of the American College of Cardiology. Feb. 8. 2011;57(6):664-71. [pmid: 21292127].
94 Bangalore S, Bhatt DL, Rother J, et al. Late outcomes after carotid artery stenting versus carotid endarterectomy: insights from a propensity-matched analysis of the Reduction of Atherothrombosis for Continued Health (REACH) Registry. Circulation. Sep. 14. 2010;122(11):1091-100. [pmid: 20805431].
95 Lindstrom D, Jonsson M, Formgren J, et al. Outcome after 7 years of carotid artery stenting and endarterectomy in Sweden - single centre and national results. Eur J Vasc Endovasc Surg. May. 2012;43(5):499-503. [pmid: 22342694].
96 Soonawala D, Middelburg RA, Egger M, et al. Efficacy of experimental treatments compared with standard treatments in non-inferiority trials: a meta-analysis of randomized controlled trials. Int J Epidemiol. Dec. 2010;39(6):1567-81. [pmid: 20837637].
97 FDA Presentation. Circulatory System Devices Panel Meeting. 2004. June 14, 2012. Available at: www.fda.gov/ohrms/dockets/ac/04/briefing/4033b1.htm.
98 Meschia JF, Brott TG, Chukwudelunzu FE, et al. Verifying the stroke-free phenotype by structured telephone interview. Stroke. May. 2000;31(5):1076-80. [pmid: 10797168].
99 Rothwell PM. Can overall results of clinical trials be applied to all patients?. Lancet. Jun. 24. 1995;345(8965):1616-19. [pmid: 7783541].
100 Bangalore S, Kumar S, Wetterslev J, et al. Carotid Artery Stenting vs Carotid Endarterectomy: Meta-analysis and Diversity-Adjusted Trial Sequential Analysis of Randomized Trials. Arch Neurol. 2010. Oct. 11. [pmid: 20937941].
101 Hirt LS. Progression Rate and Ipsilateral Neurological Events in Asymptomatic Carotid Stenosis. Stroke. 2011. Jul. 28. [pmid: 21799164].