# Methods

This report on the effectiveness of three treatment strategies for asymptomatic carotid artery stenosis is based on a systematic review of the literature. The approach, methodology, and criteria used were agreed upon by consensus of the Tufts EPC, CMS, and AHRQ staff.

## Search Strategy

We searched MEDLINE® and the Cochrane Central Register of Controlled Trials for English-language studies of adult human subjects to identify articles relevant to each key question from inception through May 2012. We searched the Food and Drug Administration (FDA) Web site, and we contacted corresponding authors of eligible studies for unpublished data on outcomes of interest. We also reviewed reference lists of systematic reviews and selected narrative reviews and primary articles. In electronic searches, we combined terms for carotid artery stenosis, endarterectomy, and stenting in the context of relevant research designs (see Appendix A for complete search strategy).

## Study Selection

We assessed titles and/or abstracts of citations identified from literature searches for inclusion, using the criteria described below. Full-text articles of potentially relevant abstracts were retrieved and a second review for inclusion was conducted by reapplying the inclusion criteria.

### Population

We included studies of adults (≥ 18 years) with asymptomatic carotid artery stenosis. Eligible stenoses included atherosclerotic narrowing of the lumen of the carotid bifurcation or the extracranial part of ICA between 50 to 99 percent, as defined by any invasive imaging modality (DSA) or noninvasive imaging modality (carotid DUS, CTA, or MRA). We included both unilateral and bilateral stenoses but excluded ipsilateral carotid occlusions (100 percent obstructions), since patients with carotid occlusions are not typically considered for revascularization.

In general, we accepted the definition of “asymptomatic” patients used in each study, which could include any of the following:

- Patients with eligible carotid stenoses and no history of any vascular territory symptoms or physical findings on neurological exam at enrollment (patients without symptoms).
- Patients with eligible carotid stenoses and a history of cerebrovascular symptoms or physical findings on neurological exam (either ipsilaterally or contralaterally, or in the vertebrobasilar territory) for > 6 months before their enrollment in the study but without any recent symptoms at enrollment (patients with remote symptoms).
- Patients with eligible carotid stenoses and a history of contralateral or vertebrobasilar symptoms and signs < 6 months before enrollment (patients with symptoms in a different vascular territory other than ipsilateral carotid).

We included studies with mixed cohorts of patients (symptomatic and asymptomatic carotid artery stenosis), provided that the results were stratified according to symptom status. We also included studies of mixed cohorts of patients who had either asymptomatic carotid artery stenosis or who were asymptomatic but had a recurrence of carotid stenosis following prior carotid intervention (CEA or CAS).

Subgroups of interest included those stratified by the following characteristics: age≥ 65 years and ≥ 80 years, sex, other baseline features (including comorbid medical diseases), clinical or anatomic features of carotid artery stenosis of > 70 percent or > 80 percent, concurrent or postoperative treatments, length of followup, and methodological quality of studies. We were also interested in the subgroup of patients who are considered to be high risk for CEA. We systematically compiled a list of factors associated with an increased risk of periprocedural adverse events (death or stroke) in patients undergoing CEA: variables found to be statistically significant in multivariate analyses of published literature for predictive models, variables listed in the CMS decision memo,18 predictors described in a published systematic review of the literature,19 those included in the reference surgical risk classification tool,20 and all study definitions for patients who were high risk for CEA (e.g., as in the Stenting and Angioplasty with Protection in Patients at High Risk for Endarterectomy[SAPPHIRE] trial).21 We created a list of these factors in three categories (angiographic, medical, and neurological), and we specifically sought data on these conditions in the included studies (Appendix B).

### Interventions

The primary interventions of interest were medical therapy alone, CEA and medical therapy, and CAS and medical therapy. Medical therapy can range from use of antiplatelets, anticoagulants, antihypertensives, lipid-lowering drugs, control of diabetes, smoking cessation, exercise, diet, or any other standard of care measures. Optimal medical therapy has changed over time and recent studies may have used a different set of medical therapies. Consequently, we developed operational definitions of the type and intensity of medical interventions used in each study (e.g. use of dual or single antiplatelet treatment, use of statins). However, we did not exclude a priori any studies that did not report on the medical treatment used or that specifically did not use a certain type of treatment (e.g. aspirin). We also considered all natural history studies as medical therapy alone studies, since we assumed that patients included in natural history studies with active followup did not undergo revascularization intervention, and would have received the “standard medical care” available at the time.

CEA included all variations of the surgical technique (e.g. eversion CEA, patch, shunt etc.) or anesthetic procedure (local or general anesthesia). CAS included all carotid intravascular interventions that involved any type of stent placement (with or without prior balloon angioplasty or concurrent use of embolic protection device). We excluded studies with patients with asymptomatic carotid stenosis undergoing an additional revascularization procedure at a different vascular site (e.g. coronary artery bypass grafting).

### Comparators

We considered the following comparisons of interest: CEA and medical therapy versus medical therapy alone, CAS and medical therapy versus medical therapy alone, and CAS and medical therapy versus CEA and medical therapy.

We excluded studies that compared different types of medical treatments. Also excluded were studies comparing different CAS techniques with each other (e.g., drug-eluting stents versus bare metal stents for CAS) and studies comparing different surgical techniques with each other (e.g., patch versus nonpatch) that did not examine a comparator of interest. We excluded studies that utilized comparisons of interventions with historical controls.

### Outcomes

For Key Questions 1 and 2, we included studies that reported only major clinical outcomes: stroke, death, myocardial infarction (MI), or other cardiovascular events. For Key Question 3, we included studies that reported safety outcomes related to a procedure or therapy (referred to as complications) or clinical outcomes, including stroke, death, or MI (referred to as adverse events) occurring within 30 days of the procedures or within 30 days of followup in the medical therapy group. The specific outcomes of interest, and the key question they addressed, are as follows:

1. Cerebrovascular events (Key Questions 1, 2, and 3)
  A. Stroke (Key Questions 1, 2, and 3)
    - Ipsilateral or any vascular territory stroke
    - Ischemic or hemorrhagic stroke
    - Stroke of any severity (e.g., minor or major)
  B. Any cerebrovascular event (e.g., stroke plus TIA, including amaurosis fugax) or TIA based on either the tissue definition or the time definition (Key Questions 1 and 2 )
2. Mortality (Key Questions 1, 2, and 3)
  A. All-cause death
  B. Cerebrovascular death
3. Composite cardiovascular outcomes (Key Questions 1, 2, and 3)
4. Other periprocedural adverse events and complications (Key Question 3)
  A. Periprocedural MI
  B. Periprocedural composite outcomes
  C. Cranial nerve palsy
  D. Bleeding complications at the surgical or the vascular access site.

### Study designs

For Key Question 1a that addressed the long-term clinical outcomes of medical therapy alone, we included prospective cohort studies and the medical therapy arm of eligible randomized controlled trials (RCTs) or prospective nonrandomized comparative studies of patients that underwent CEA for ipsilateral asymptomatic or contralateral symptomatic carotid stenosis.

For all other Key Questions comparing treatment strategies, we included both RCTs and nonrandomized (retrospective or prospective) comparative studies. We included nonrandomized comparative studies that analyzed either clinical or administrative datasets, provided that outcome data for patients diagnosed and coded as having asymptomatic carotid stenosis were available. When percent stenosis was not clearly reported in studies based on administrative dataset analyses, we assumed that all patients had a carotid stenosis of at least 50 percent.

### Sample size and duration of followup

Studies with at least 30 patients with a minimum average followup of 12 months were included to evaluate Key Question 1a (medical therapy alone). These criteria were chosen to both minimize the bias related to retrospective analyses and to set a minimum level of power and applicability.

For all other Key Questions comparing treatment strategies, we included studies with at least 30 patients per intervention group and any duration of followup.

## Data Extraction

Items extracted from each study included first author, year, country, funding source, study design, inclusion and exclusion criteria, including study definitions of asymptomatic carotid stenosis, imaging modality used (and related diagnostic and quality assurance criteria) for determining degree of stenosis (see Appendix B for a sample data extraction form). For RCTs, we recorded the method of randomization, allocation concealment, patient and outcome assessor blinding, and whether results were reported on an intention-to-treat basis. For nonrandomized studies, we also recorded study design and analysis methods used to adjust potential confounders. Specific population characteristics for each treatment group included demographics such as age and sex, and percentage of octogenarians, patients with hypertension, diabetes, atrial arrhythmias, smoking, coronary artery disease, peripheral arterial disease, history of previous TIA or stroke, history of previous CEA or CAS, patients with severe carotid stenosis (>70 or >80 percent stenosis), and patients with contralateral occlusion. Details regarding stenting techniques (including type of stent, use of embolic protection device) surgical techniques (use of patch, shunt, eversion, and type of anesthesia), and/or medical interventions were also extracted.

For each outcome of interest, we recorded the exact study definitions used, the baseline screening methods, the frequency of followup, the duration of followup and the methodology for outcome ascertainment of stroke, including whether a neurologist was part of the team of outcome adjudication. In prospective cohort studies of medical treatment, we extracted or calculated incidence rates of the events of interest expressed in person-years of followup, based on raw data or Kaplan-Meier estimates. When available, data on incidence rates were extracted from published Kaplan-Meier curves, after digitization. For comparative studies, data on numbers of events and persons at risk were extracted in order to calculate relative effect size estimates. Adjusted relative risk estimates were also recorded, when available. Periprocedural safety and adverse event data were also extracted.

## Quality Assessment

We used predefined criteria to grade study quality as A, B, or C to assess the risk of bias. This system defines a generic grading system that is applicable to varying study designs including RCTs, nonrandomized comparative studies, and observational studies.22 A summary of the methodological aspects we considered as quality items is provided in the extraction form (Appendix B.2, Table L).

We also examined study quality items relating to the diagnostic methodologies for the determination of carotid stenosis, the interventions used, and the outcome ascertainment, whenever applicable. For the diagnostic methodology used to determine the extent of carotid artery stenosis, we recorded whether the authors reported on the following items: central, blinded reading of images, one or multiple readers, for ultrasound laboratories whether the lab used a technique that was validated previously against a gold-standard methodology (i.e. DSA), accreditation by the Intersocietal Commission for the Accreditation of the Vascular Laboratories (ICAVL) or the American College of Radiology (ACR), reporting of diagnostic accuracy metrics use of confirmatory, reference imaging technique (CTA, MRA, and DSA). For studies examining interventional techniques, we recorded whether certification requirements (for volume of procedures or performance standards) were reported for surgeons and interventionists. Additional considerations were given to evaluate the quality of the outcome ascertainment, whether this was performed blinded to clinical status or treatment allocation and whether a neurologist assessed the outcome of stroke.

- A (good)
  - Quality-A studies have the least bias and results are considered valid. A study that adheres mostly to the commonly held concepts of high quality including the following: a formal randomized controlled study; clear description of the population, setting, interventions, and comparison groups; appropriate measurement of outcomes; appropriate statistical and analytic methods and reporting; no reporting errors; less than 20 percent dropout; clear reporting of dropouts; and no obvious bias.
- B (fair/moderate)
  - Quality-B studies are susceptible to some bias, but it is not sufficient to invalidate the results. They do not meet all the criteria in quality-A studies because they have some deficiencies, but none likely to cause major bias. However, none of them introduce a significant bias.
- C (poor)
  - Quality-C studies have significant biases that have significant flaws that imply biases of various types that may invalidate the study results. These studies introduce major errors in methods, analysis or discrepancies in reporting results.

## Applicability

Applicability of study results was assessed on the basis of reporting of the following factors in stratified analyses: age groups of ≥ 65 years and ≥ 80 years, sex, other baseline clinical characteristics including comorbid medical diseases, medical therapy at baseline, and clinical or anatomic features of carotid artery stenosis (> 70 percent or > 80 percent stenosis). In addition, studies had applicability graded on the basis of whether they were conducted in tertiary centers or community centers.

## Data Analysis

### Studies of medical therapy alone

We calculated the incidence rate of events ―that is, the incidence density―as the ratio = number of events/average person-time of followup along with the 95 percent exact Poisson confidence interval (95 percent CI) in studies when numerical data of events and an average followup person-time were available.23 For outcomes investigated in at least five studies, we obtained summary estimates of incidence rates by fitting a generalized linear random effects meta-analysis model for count data with the exact Poisson likelihood.24 Studies that reported incidence rates with their 95 percent CIs, without providing the number of events or person-time, were included in sensitivity analyses using an inverse variance random effects meta-analysis model (DerSimonian–Laird).25 In this report, we express the units as percent per year instead of the number of events per 100 person-years.

To examine trends in the incidence rates of outcomes over time, we performed meta-regression analyses with the last year of recruitment in each study (recruitment closure year) as a continuous covariate.26 Because we were particularly interested in the incidence rates of events occurring during contemporary medical treatment, we conducted a subgroup analysis for studies that reported recruitment year 2000 or after, based on the availability or an increased utilization of medications such as statins. We conducted further exploratory subgroup and meta-regression analyses based on a prespecified set of clinically relevant explanatory variables and only for the outcomes with adequate analyzable information (≥ 5 studies). These restrictions were put in place in order to obtain precise estimates of subgroup-specific incidence rates and to minimize the risk of false-positive results,27 These exploratory analyses included the quality of studies (A or B versus C), operational definitions on the intensity of reported treatment (stratification of studies by the reported proportion of patients under treatment with anti-thrombotic agents or statins), the extent of anatomical stenosis (> 70 percent versus 50–70 percent stenosis) and finally the inclusion of patients with contralateral CEA in the each study cohort versus never-operated patients. Statistically significant differences between subgroups were examined with meta-regression tests for interaction.

### Comparative studies

For comparative studies, relative risk (RR) estimates were calculated from numerical event data. RCTs and nonrandomized comparative studies were analyzed separately and analyses were stratified by study designs (RCTs, nonrandomized comparative-clinical and nonrandomized comparative-administrative studies). We performed meta-analysis using a random effects model and reported the results as summary relative risks (RRs). Heterogeneity was tested with the Q-statistic and quantified with I^2^. Statistical significance for all tests, other than those of heterogeneity, was defined as a two-sided P-value < 0.05. No adjustment for multiple comparisons was performed. When we identified discrepancies between published and unpublished data for a study, or when we identified extreme clinical heterogeneity, we refrained from conducting meta-analyses to synthesize data. In RCTs comparing treatments, when possible, we also estimated summary incidence rates of ipsilateral stroke for each of the treatment arms.

## Grading the Strength of Evidence

We graded the strength of the body of evidence for each analysis within each key question per the AHRQ methods guide.22 Risk of bias was defined as low, medium, or high on the basis of the corresponding quality rating A, B, or C, respectively, of individual studies. We assessed the consistency of the data, which was classified as either “no inconsistency” or “inconsistency present” (or “not applicable” if there was only one study). The direction, magnitude, and statistical significance of findings from all studies were evaluated in assessing consistency, and logical explanations were provided in the presence of equivocal results. We also assessed the directness of evidence and the precision of the evidence on the basis of the degree of certainty surrounding an effect estimate. A precise estimate was considered to be an estimate that would allow for a clinically useful conclusion. An imprecise estimate was one for which the confidence interval was wide enough to preclude a conclusion.

For Key Question 1a, evaluating effectiveness of medical therapy alone, the strength of evidence was graded on the basis of individual studies (prospective cohort studies and the medical therapy arms in eligible trials) rated quality-A or -B. For all other key questions comparing treatment strategies, the strength of evidence was graded on the basis of individual RCTs rated quality-A or -B. The quality-C studies were excluded from the strength-of-evidence assessment but are described in detail in the results section of this report.

Grades were assigned according to our level of confidence that the evidence reflects the true effect for the interventions of interest and were defined as follows:

High. There is a high level of assurance that the findings of the literature are valid with respect to the relevant comparison. No important scientific disagreement exists across studies. At least two quality-A studies are required for this rating. In addition, there must be evidence regarding important clinical outcomes. Further research is very unlikely to change our confidence in the estimate of effect.

Moderate. There is a moderate level of assurance that the findings of the literature are valid with respect to the relevant comparison. Little disagreement exists across studies. Moderately rated bodies of evidence contain fewer than two quality-A or-B studies or such studies lack long-term outcomes of relevant populations. Further research may change our confidence in the estimates of effect and may change the estimate.

Low. There is a low level of assurance that the findings of the literature are valid with respect to the relevant comparison. Underlying studies may report conflicting results. Further research is likely to change our confidence in the estimate of effect and may change the estimate for this outcome.

Insufficient. Evidence is either unavailable or does not permit estimation of an effect due to a lack of data or sparse data. In general, when only one study has been published, the evidence was considered insufficient, unless the study was particularly large, robust, and of good quality.