# Executive Summary

## Background

Carotid artery stenosis is an important cause of ischemic stroke and is increasingly prevalent from the fifth decade of life onward. Since carotid artery atherosclerosis can largely progress silently and unpredictably, the first manifestation can be a debilitating or fatal stroke. Asymptomatic carotid artery stenosis affects approximately 7 percent of women and over 12 percent of men, older than 70 years of age. Therapeutic options include carotid endarterectomy (CEA) and medical therapy, carotid angioplasty and stenting (CAS) and medical therapy, or medical therapy alone. However, the optimal therapeutic management strategy for patients with asymptomatic carotid stenosis is unclear. The Centers for Medicare and Medicaid Services (CMS) is interested in a systematic review of the literature on these three treatment strategies for patients with asymptomatic carotid stenosis. The Coverage and Analysis Group at the CMS requested this report from the Technology Assessment Program (TAP) at the Agency for Healthcare Research and Quality (AHRQ). AHRQ assigned this report to the Tufts Evidence-based Practice Center (Tufts EPC) (Contract number HSSA 290 2007 10055 I).

## Methods

The present technology assessment provides a systematic review of the literature of treatment strategies for patients with asymptomatic carotid artery stenosis. The following key questions were formulated in consultation with CMS and AHRQ.

1. In asymptomatic patients with carotid artery stenosis, what is the evidence on long-term clinical outcomes (at least 12 months of followup) including stroke, death, myocardial infarction, and other cardiovascular events the following interventions?
  a. Medical therapy alone
  b. CEA and medical therapy versus medical therapy alone
  c. CAS and medical therapy versus medical therapy alone
  d. CAS and medical therapy versus CEA and medical therapy
2. Among comparative studies (CEA and medical therapy versus medical therapy alone, CAS and medical therapy versus medical therapy alone, CAS and medical therapy versus CEA and medical therapy), what is the impact of the following patient, intervention, and study characteristics on treatment effect?
  - Demographic and other baseline features including the assessment the applicability of studies to patients ≥ 65 years with asymptomatic carotid artery stenosis, subgroup of patients ≥ 80 years, and sex
  - Clinical and anatomic features of carotid artery stenosis
  - Average or high risk for CEA due to comorbid diseases
  - Types of stents used and use of embolic protection devices
  - Concurrent and postoperative treatments
  - Length of followup
  - Methodological quality of studies
3. Among comparative studies (CEA and medical therapy versus medical therapy alone; CAS and medical therapy versus medical therapy alone; CAS and medical therapy versus CEA and medical therapy), what is the evidence on adverse events and complications during the periprocedural period?

### Search strategy

A comprehensive search of the scientific literature was conducted in MEDLINE^®^ and the Cochrane Central Register of Controlled Trials for English-language studies of adult human subjects from inception through May 2012. In addition, bibliographies of systematic reviews and selected narrative reviews were searched to identify additional citations. We also searched the Food and Drug Administration (FDA) Web site, and we contacted corresponding authors of eligible studies for unpublished data on outcomes of interest.

### Study eligibility criteria

#### Population

Eligible studies included those of adults (≥ 18 years) with asymptomatic carotid artery stenosis. Eligible stenoses included atherosclerotic narrowing of the lumen of the carotid bifurcation or the extracranial part of the internal carotid artery between 50 to 99 percent. We accepted the definition of “asymptomatic” patients used in each study. We included studies with mixed cohorts of patients (symptomatic and asymptomatic carotid artery stenosis), provided that the results were stratified according to symptom status.

#### Intervention and comparator

We included studies of medical therapy alone, CEA and medical therapy compared with medical therapy alone, CAS and medical therapy compared with medical therapy alone, and CAS and medical therapy compared with CEA and medical therapy.

#### Outcomes

For Key Questions 1 and 2, we included studies that reported only major clinical outcomes: stroke, death, myocardial infarction (MI), and other cardiovascular events. For Key Question 3, we included studies that reported safety outcomes related to a procedure or therapy (referred to as complications) or clinical outcomes, including stroke, death, or MI (referred to as adverse events) occurring within 30 days of the procedures or within 30 days of followup in the medical therapy group.

#### Study designs

For Key Question 1a evaluating long-term clinical outcomes of medical therapy alone, we included prospective cohort studies and the medical therapy arm of eligible randomized controlled trials (RCTs) or prospective nonrandomized comparative studies.

#### Sample size and duration of followup

For Key Question 1a, studies with at least 30 patients with a minimum average followup of 12 months were included. For all other key questions comparing treatment strategies, we included at least 30 patients per intervention group and any duration of followup.

### Data analysis

For studies of medical therapy alone where numerical data of events and average followup person-time were available, we calculated the incidence rate of events and its 95 percent exact Poisson confidence interval (95 percent CI). Summary estimates of incidence rates were constructed by fitting a generalized linear random effects meta-analysis model and were expressed as percent per year (instead of number of events per 100 person-years). We performed meta-regression analyses with the last year of recruitment in each study to evaluate changes in the rates of events over time. We conducted further exploratory subgroup and meta-regression analyses based on a prespecified set of clinically relevant explanatory variables and only for the outcomes with at least five studies.

For comparative studies, we conducted meta-analysis using a random effects model and reported the results as summary relative risk (RR). RCTs and nonrandomized comparative studies were analyzed separately. When we identified discrepancies between published and unpublished data for a study, or extreme clinical heterogeneity between studies (i.e, inclusion of different patient groups), we refrained from conducting a meta-analysis but presented estimates of each study in forest plots. In RCTs comparing treatments, we also estimated summary incidence rates of ipsilateral stroke for each of the treatment arms.

### Study quality and applicability

We used a three-level (A or low risk of bias, B or moderate risk of bias, and C or high risk of bias) system per the AHRQ methods guide to denote the methodological quality (risk of bias) of each study. Quality-A studies have the least bias and results are considered valid. Quality-B studies are susceptible to some bias, but it is not sufficient to invalidate the results. Quality-C studies have significant biases that may invalidate the study results.

Study applicability was described using study specific characteristics such as age groups of ≥ 65 years and ≥ 80 years, sex, other baseline clinical features including comorbid medical diseases, center characteristics, medical therapy at baseline, and clinical or anatomic features of carotid artery stenosis (> 70 percent or > 80 percent stenosis).

### Strength of evidence

For each key question, grading of the strength of evidence provides an overall summary of risk of bias in individual studies, directness and precision of the evidence, and the consistency across studies. We used a four-category grading system per the AHRQ methods guide to grade the strength of evidence. For Key Question 1a, evaluating effectiveness of medical therapy alone, the strength of evidence was graded on the basis of individual studies (prospective cohort studies and trials with the medical therapy arms) rated quality-A or -B. For all other key questions comparing treatment strategies, the strength of evidence was graded on the basis of individual RCTs rated quality-A or -B. The quality-C studies were excluded from the strength-of-evidence assessment but are described in detail in full text of the report.

Grades were assigned according to our level of confidence that the evidence reflects the true effect for the interventions of interest and were defined as follows:

- High strength of evidence indicates that there is a high level of assurance that the findings of the literature are valid with respect to the relevant comparison and no important scientific disagreement exists across studies. Further research is very unlikely to change our confidence in the estimate of effect.
- Moderate strength of evidence indicates that there is a moderate level of assurance that the findings of the literature are valid with respect to the relevant comparison and little disagreement exists across studies. Further research may change our confidence in the estimates of effect and may change the estimate.
- Low strength of evidence indicates that there is a low level of assurance that the findings of the literature are valid with respect to the relevant comparison. Underlying studies may report conflicting results. Further research is likely to change our confidence in the estimate of effect and may change the estimate for this outcome.
- Insufficient strength of evidence indicates that evidence is either unavailable or does not permit estimation of an effect owing to a lack of data or sparse data. In general, when only one study has been published, the evidence was considered insufficient, unless the study was particularly large, robust, and of good quality.

These ratings provide a shorthand description of the strength of evidence supporting the major questions we addressed. However, they by necessity may oversimplify the many complex issues involved in the appraisal of a body of evidence. It is important to remember that the individual studies evaluated in formulating the composite rating differed in their design, reporting, and quality. The strengths and weaknesses of the individual reports, as described in detail in the text and tables, should also be taken into consideration.

## Results

The literature search identified 60 eligible studies in 68 articles. In general, the definition of “asymptomatic” patients used in each study was heterogeneous. These included any of the following at enrollment: those without symptoms, those with symptoms present for > 6 months before their enrollment in the study but recently (within 6 months) asymptomatic, or those with symptoms in a vascular territory other than ipsilateral carotid (e.g., vertebrobasilar territory). All eligible studies are described in detail in full-text of the report. Only studies that contributed to grading the strength of evidence are described in the executive summary.

### Key Question 1

#### Medical therapy alone (Key Question 1a)

There is moderate strength of evidence among 20 quality-A and -B studies that medical therapy alone can reduce the incidence rate of ipsilateral stroke over time in patients with asymptomatic carotid stenosis.

In 20 quality-A and -B studies of (any) medical therapy alone, the summary incidence rate of ipsilateral stroke was 1.59 (95% CI = 1.21, 2.09) percent per year of followup. The summary incidence rate estimate of 13 studies reporting the combined outcome of ipsilateral stroke or transient ischemic attack (TIA) was 4.56 (95% CI = 3.79, 5.47) percent per year of followup. The summary incidence rate for any stroke in 12 studies was 3.18 (95% CI = 2.32, 4.35) and for any stroke or TIA in five studies was 5.71 (95% CI = 3.30, 9.90) percent per year of followup. The summary incidence rate of all-cause death across 11 studies was 4.38 (95% CI = 3.00, 6.41) percent per year of followup.

In subgroup analyses, use of statins by ≥ 25 percent (vs. < 25 percent) of the study population and use of antiplatelet therapy by ≥ 50 percent (vs. < 50 percent) of the study population was associated with significantly decreased rates of ipsilateral stroke.

##### Changes in outcome incidence over time across studies

Meta-regression analyses showed that the incidence rates of ipsilateral stroke was significantly decreased in studies with a recruitment closure year between 2000 and 2010 (recent studies) as compared with older studies (1.13 versus 2.38 percent per year, P for interaction = 0.0008). The summary incidence rate of ipsilateral stroke or TIA, any territory stroke, and death was also significantly decreased in recent studies as compared with older studies.

#### CEA and medical therapy versus medical therapy alone (Key Question 1b)

There is moderate strength of evidence (that is not applicable to contemporary medical treatment) among three quality-A RCTs (the Veterans Affairs Cooperative Study [VA], the Asymptomatic Carotid Atherosclerosis Study (ACAS), and the Asymptomatic Carotid Atherosclerosis Trial [ACST]) that CEA and medical therapy can reduce the risk of ipsilateral stroke as compared with medical therapy alone, which was demonstrated by all three trials. The results from these trials are not applicable to contemporary clinical practice, as they do not compare CEA with current best medical therapy. Patients with asymptomatic carotid stenosis did not receive at randomization what is considered current best medical therapy, including the use of statins and targets for the treatment of blood pressure and diabetes. The meta-analyses of these RCTs showed no difference between the two treatment groups for the risk of any death, fatal stroke, or CVD death.

##### Ipsilateral stroke (including any stroke or death within 30 days)

All three RCTs contributed to the analysis of ipsilateral stroke (defined as any stroke or death within 30 days or subsequent ipsilateral stroke). In a meta-analysis, the CEA had a 31 percent significantly decreased risk of ipsilateral stroke (including perioperative stroke or death) compared with the medical therapy (summary RR = 0.69, 95% CI = 0.55, 0.87) without statistical heterogeneity (I^2^ = 0.0%, P = 0.90).

##### Any stroke (including any death within 30 days)

All three RCTs reported the outcome of any stroke, defined as events of perioperative stroke or death or subsequent nonperioperative any territory stroke. In a meta-analysis, the CEA had a 32 percent significantly decreased risk of any stroke (including perioperative stroke or death) as compared with the medical therapy group (summary RR = 0.68, 95% CI = 0.56, 0.82) without statistical heterogeneity (I^2^ = 17.7%, P=0.30).

##### Any stroke or death

All three RCTs reported that the CEA had a nonsignificantly decreased risk for the combined endpoint of any stroke or death compared with the medical therapy. A meta-analysis showed no significant difference between the two groups (summary RR = 0.94, 95% CI = 0.85, 1.03) without statistical heterogeneity (I^2^ = 19%, P=0.29).

##### Death

A meta-analysis of the three RCTs showed no significant difference in death between the two intervention groups (summary RR = 1.05, 95% CI =0.97, 1.14) and no statistical heterogeneity (I^2^ = 0.0%, P=0.60). When the meta-analysis was restricted to fatal stroke, the CEA had a nonsignificantly decreased risk by 21 percent as compared with the medical therapy (summary RR = 0.79, 95% CI =0.57, 1.08) and no statistical heterogeneity (I^2^ = 0.0%, P=0.61).

##### CVD outcomes

A meta-analysis of three RCTs on cardiovascular deaths showed no significant difference between the two groups (summary RR = 1.01, 95% CI = 0.82, 1.25) with statistically nonsignificant heterogeneity (I^2^ = 37.6%, P=0.20).

#### CAS and medical therapy versus medical therapy alone (Key Question 1c)

The strength of evidence was graded as insufficient because of a lack of RCTs.

#### CAS and medical therapy versus CEA and medical therapy (Key Question 1d)

No statistically significant difference in the risk of ipsilateral stroke or the risk of the composite endpoint of ipsilateral stroke was found between CAS and CEA in two RCTs (one quality-A and one quality-B). The strength of evidence is graded as insufficient because in these trials, the included population had extreme clinical heterogeneity (i.e., one study representing a population of low-to-average risk and the other representing a high-risk population). Therefore, these studies were not combined in meta-analyses. Furthermore, there was selective reporting of outcomes of interest.

The Carotid Revascularization Endarterectomy versus Stenting Trial (CREST) and the Stenting and Angioplasty with Protection in Patients at High Risk for Endarterectomy (SAPPHIRE) trial enrolled both symptomatic and asymptomatic patients who were assigned to treatments on the basis of stratified randomization according to symptom status. Thus, the treatment assignment was randomized among the subgroup of patients with asymptomatic carotid stenosis. However, among this subgroup, neither trial was powered to detect differences in the primary outcome (composite endpoint). Therefore, the failure to find statistically significant differences does not rule out the possibility that real differences exist between interventions. CREST was conducted as an equivalence trial but was analyzed as a noninferiority trial in the FDA submission and as a superiority trial in the published paper. The SAPPHIRE trial used group sequential design and was analyzed as a noninferiority trial in the published papers. In this trial (SAPPHIRE), there were differences in reporting between the published paper and unpublished data on the FDA Web site. One additional quality-B RCT (Brooks 2004) was a single-center trial and in this trial, no cerebrovascular outcomes occurred in either intervention group.

##### Ipsilateral stroke (including any stroke within 30 days)

Two RCTs (CREST and SAPPHIRE) reported data on ipsilateral stroke. CREST reported it as a composite of any periprocedural stroke (within 30 days) or postprocedural (> 30 days) stroke ipsilateral to the treated carotid artery at 4-year followup. CREST reported a nonsignificantly increased risk of ipsilateral stroke at the 4-year followup in CAS as compared with CEA (adjusted HR = 1.86; 95% CI = 0.95, 3.66). The SAPPHIRE trial defined it as ipsilateral stroke at 1 year, for which the data were obtained from the FDA Web site. The SAPPHIRE trial reported similar rates of ipsilateral stroke between CAS and CEA (5.2% vs. 5.3%).

##### Any stroke (including any death within 30 days)

The SAPPHIRE trial reported data on any stroke, with no statistical significance between groups (RR = 1.12, 95% CI = 0.51, 2.43)

##### Any stroke or TIA (including any death within 30 days)

One RCT (Brooks 2004) examined the outcome of any stroke or TIA but reported zero events for both treatment groups.

##### Any stroke or death

CREST reported a nonsignificantly increased risk of any stroke or death in CAS as compared with CEA (adjusted HR = 1.86; 95% CI = 0.95, 3.66). The SAPPHIRE trial did not report data for this outcome.

##### Death

The SAPPHIRE trial reported a nonsignificantly decrease in the risk of death in CAS as compared with CEA (RR = 0.47, 95% CI = 0.18, 1.20). CREST did not report data for this outcome.

##### CVD outcomes

No studies reported long-term data for CVD outcomes.

##### Composite endpoint including ipsilateral stroke

###### Any periprocedural stroke, MI, or death or postprocedural ipsilateral stroke

Two RCTs (CREST and SAPPHIRE) reported data on this composite outcome, which represented the primary outcome of CREST and SAPPHIRE trials over the 4-year and 3-year followup, respectively. Neither trial reported a statistically significant difference between CAS and CEA. The confidence interval of the RR estimate in each study was wide and the observed point estimates were in opposite directions (unfavorable for CAS in CREST [HR = 1.17, 95% CI = 0.69, 1.98] and favorable in the SAPPHIRE trial [RR = 0.73, 95% CI = 0.47, 1.14]). However, neither trial was powered to detect a significant difference in the primary outcome among subgroup of patients with asymptomatic carotid stenosis. Therefore, the failure to find statistically significant differences does not rule out the possibility that real differences exist between interventions.

###### Any periprocedural stroke, any death, or postprocedural ipsilateral stroke

Two RCTs (CREST and SAPPHIRE) reported data on this composite outcome. CREST reported a statistically nonsignificantly increased HR (adjusted for age and sex) with CAS as compared with CEA for this composite outcome (HR = 1.86, 95% CI = 0.95, 3.66). The SAPPHIRE trial reported that CAS had a statistically nonsignificantly decreased risk of this composite outcome as compared with CEA (RR = 0.54, 95% CI =0.28, 1.02). The observed point estimates in these two trials were extremely discordant. There were differences between published and unpublished data for the SAPPHIRE trial.

#### Summary incidence rate by treatment group

The summary incidence rate of quality-A and -B studies of medical therapy alone was 1.59 percent per year of followup. In a subgroup analysis, the summary incidence rate of ipsilateral stroke was significantly decreased in recent studies (recruitment closure year between 2000 and 2010) compared with older studies, recruitment closure year before 2000 (1.1 versus 2.3 percent per year of followup).

Five RCTs, namely the VA, ACAS, ACST, CREST, and SAPPHIRE trials, contributed to the incidence rate meta-analysis of the CEA and medical therapy arm. The summary incidence rate of ipsilateral stroke with CEA and medical therapy was 1.42 percent per year of followup. In a subgroup analysis of patients who had CEA and medical therapy, the summary incidence rate of ipsilateral stroke was significantly decreased in recent studies (recruitment closure year between 2000 and 2010) studies compared with older studies (recruitment closure year before 2000) studies (1.3 versus 1.6 percent per year of followup). For the two RCTs that reported long-term data, the summary incidence rate of ipsilateral stroke in the CAS and medical therapy arm was 1.61 percent per year of followup (in CREST) and 5.12 percent per year of followup (in SAPPHIRE). Both studies recruited patients after the year 2000.

### Key Question 2 (Subgroups and treatment effect)

#### CEA and medical therapy versus medical therapy alone

The strength of evidence is graded as insufficient, because two quality-A RCTs (ACAS and ACST, in two publications) reported subgroup-specific data for three outcomes that cannot be combined. The outcomes evaluated for subgroups were ipsilateral stroke, including perioperative stroke or death, in the ACAS trial, nonperioperative carotid territory stroke in ACST with 5-year followup, and any territory stroke in ACST with 10-year followup. In addition, there was insufficient information on certain subgroups. The VA trial evaluated long-term outcomes and did not report any subgroup-specific data.

#### Demographic and other preoperative (baseline) features of studied patients

##### Age: Subgroup of patients ≥ 65 years

ACAS reported that patients < 68 years of age in the CEA group had a significantly decreased risk of ipsilateral stroke as compared with the medical therapy group but those ≥ 68 years of age had no difference between the two treatment groups. ACST reported that patients < 75 years of age had a significantly decreased risk of nonperioperative carotid territory stroke at 5 years or a significantly decreased risk of any territory stroke at 10 years with CEA and medical therapy as compared with medical therapy alone. But, patients ≥ 75 years of age had no significant difference between the two treatment groups.

##### Age: Subgroup of patients ≥ 80 years

No trials reported data for the subgroup of patients ≥ 80 years of age. ACAS excluded such patients. In the 10-year followup of ACST, both men and women < 75 years of age had significantly decreased annual rates of any stroke in the CEA group as compared with the medical therapy group. Similar benefit was not reported for the subgroup of men or women ≥ 75 years of age.

##### Sex

The VA trial included only men and the remaining two RCTs included a higher proportion of men than women. ACAS reported that during a projected 5-year followup, according to the Kaplan–Meier analysis, men had a significantly decreased risk of ipsilateral stroke (including perioperative stroke or death) in the CEA group than in the medical therapy group. During the 5-and 10-year followup of ACST, both men and women received greater benefits with CEA than with medical therapy for the outcome of nonperioperative carotid territory stroke or any stroke, respectively.

##### Clinical and anatomic features of carotid artery stenosis

Regardless of the degree of stenosis, in ACST, patients in the CEA group had a decreased risk of carotid territory stroke at 5 years as compared with patients in the medical therapy group, while in the 10-year followup, only a subgroup of patients with 70–89 percent stenosis had decreased annual rates of any stroke in the CEA group as compared with the medical therapy group.

In ACAS, patients with prior symptoms due to contralateral carotid stenosis or prior contralateral CEA had a reduced risk of ipsilateral stroke (including perioperative stroke or death) in the CEA group as compared with the medical therapy group on the basis of 5-year projected estimates from the Kaplan–Meier analysis. However, over a median 2.7-year followup in ACAS, there were more events in the CEA group than in the medical therapy group among patients who had prior symptoms due to contralateral carotid stenosis or prior contralateral CEA. In ACST at the 10-year followup, patients with prior symptoms due to contralateral carotid stenosis or prior contralateral CEA had no difference between the two treatment groups.

##### Average or high risk for CEA owing to comorbid diseases

All three RCTs excluded the majority of patients who were believed to be at high risk for CEA owing to associated medical illnesses.

##### Concurrent and postoperative treatment

Only the 10-year followup of ACST evaluated any nonperioperative stroke stratified by concurrent use of medications (antihypertensive therapy, antithrombotic therapy, and lipid-lowering therapy) at study entry. Few patients in these trials were receiving lipid-lowering therapy at study entry. Regardless of the usage of antihypertensive or lipid-lowering therapy, as compared with the medical therapy group, the CEA group had a significantly decreased risk of carotid artery territory stroke at 5 years and decreased annual rates of any stroke at 10 years.

##### Length of followup

Overall estimates of ipsilateral stroke or any stroke after CEA decreased with followup, but estimates of death did not change regardless of whether 5- or 10-year data were used from ACST.

##### Methodological quality of studies

All three RCTs were rated quality A.

#### CAS and medical therapy versus medical therapy alone (Key Question 2)

The strength of evidence is graded as insufficient because of the lack of RCT data.

#### CAS versus CEA (Key Question 2)

The strength of evidence is graded as insufficient because there was insufficient information or only one of the three RCTs (CREST, SAPPHIRE, and Brooks 2004) reported data on subgroups of interest.

#### Demographic and other baseline features of studied patients

##### Age: Subgroup of patients ≥ 65 years

The average age of patients enrolled in RCTs ranged from 66.6 to 72.6 years. However, no study provided data for the age subgroups < 65 years or ≥ 65 years; thus, between these subgroups we could not evaluate whether the treatment effect of CAS was different from CEA.

##### Age: Subgroup of patients ≥ 80 years

No subgroup analysis by patient age was reported in asymptomatic carotid stenosis.

##### Sex

CREST reported data stratified by sex in asymptomatic patients. Both men and women had nonsignificantly increased hazard ratio for the primary composite endpoint, stroke, and stroke or death with CAS as compared with CEA.

##### Clinical and anatomic features of CAS

The SAPPHIRE trial included only patients with > 80 percent carotid stenosis and reported no significant differences between CAS and CEA for ipsilateral stroke, any stroke, death, or composite primary endpoint.

##### Average or high risk for CEA due to comorbid diseases

All patients included in the SAPPHIRE trial were considered to be at high risk for adverse events on the basis of the clinical and anatomic features specified in the trial eligibility criteria.

##### Types of stents used and use of embolic protection devices

Data on the type of stents and embolic protection devices were reported by three RCTs (CREST, SAPPHIRE, and Brooks 2004). The trials did not report subgroup data according to the specific type of stent used. The Brooks 2004 trial did not use embolic protection devices. The majority of patients in trials that reported long-term outcomes (CREST and SAPPHIRE) underwent CAS with embolic protection devices. These trials did not report subgroup-specific data for the patients that did not receive such devices. Therefore, the impact of the use of embolic protection devices on the treatment effect of CAS could not be evaluated.

##### Concurrent and postoperative treatments

The two RCTs (CREST and SAPPHIRE) employed similar medical treatment for perioperative management (dual antiplatelet therapy for the CAS group and single antiplatelet therapy for the CEA group) and long-term management of patients. Neither RCT reported data relevant to examination of the impact of various medical treatments on clinical outcomes.

##### Length of followup

Only the SAPPHIRE trial reported data for 1- and 3-year followup. The 1-year data showed a significant 53 percent reduction in the risk of the primary outcome of any periprocedural stroke, MI or death, or postprocedural ipsilateral stroke with CAS over CEA (RR = 0.47, 95% CI = 0.25, 0.89); this effect was no longer significant at 3 years (RR = 0.73, 95% CI = 0.47, 1.14).

##### Methodological quality of studies

Data for the long-term efficacy of CAS as compared with CEA were reported in one quality-A RCT (CREST) and one quality-B RCT (SAPPHIRE). The observed point estimates for outcomes were in opposite directions reflecting inclusion of different patient populations.

### Key Question 3 (Outcomes occurring within 30 days)

#### CEA and medical therapy versus medical therapy alone

Two quality-A RCTs (VA and ACAS) showed an increased risk of adverse events including any stroke, death, or MI with CEA and medical therapy as compared with medical therapy alone during a 30-day period. The strength of evidence is graded as moderate for periprocedural outcomes because these results may not translate to contemporary clinical practice. In these trials, patients with asymptomatic carotid stenosis did not receive at randomization what is currently considered the best medical therapy or contemporary postoperative medical management.

The periprocedural period for the medically treated patients was defined as 30 days and 42 days after randomization in the VA and ACAS, respectively. We did not include ACST in evaluating this outcome, as the definition of perioperative morbidity and mortality in the ACST medical therapy group differed considerably from the definitions used in the other two trials.

##### Any periprocedural stroke

Two RCTs (VA and ACAS) reported a significantly higher risk of any stroke during the periprocedural period in the CEA than during the corresponding followup period in the medical therapy (summary RR = 5.94, 95% CI = 2.06, 17.12). There was no statistical heterogeneity (I^2^ = 0.0%, P=0.91).

##### Periprocedural death

Two RCTs (VA and ACAS) reported a nonsignificantly higher risk of death during periprocedural period in the CEA than during the corresponding followup period in the medical therapy (summary RR = 3.68, 95% CI = 0.77, 17.72). There was no statistical heterogeneity (I^2^ = 0.0%, P=0.82).

##### Periprocedural MI

Two RCTs (VA and ACAS) reported a nonsignificantly higher risk of MI during periprocedural period with CEA than during the corresponding followup period in the medical therapy (summary RR = 8.39, 95% CI = 1.00, 70.33). There was no statistical heterogeneity (I^2^ = 0.0%, P=0.39).

##### Periprocedural composite outcomes (Stroke or death with or without MI during the periprocedural period)

The VA and ACAS provided data on periprocedural composite outcomes. The risk of stroke or death without MI during periprocedural period was significantly higher with CEA than during the corresponding followup period with medical therapy (summary RR = 5.35, 95% CI = 2.24, 12.78), without statistical heterogeneity (I^2^ = 0.0%, P=0.68). The risk of stroke or death with MI during periprocedural period was significantly increased in CEA than during the corresponding followup period in the medical therapy (summary RR = 6.14, 95% CI 2.60, 14.52) without statistical heterogeneity (I^2^ = 0.0%, P=0.92).

##### Periprocedural cranial nerve palsy

One RCT reported cranial nerve palsy after CEA but no such events were reported during the corresponding followup period after medical therapy.

##### Periprocedural bleeding complications

RCTs reported no major bleeding events during the periprocedural period.

#### CAS and medical therapy versus medical therapy alone (Key Question 3)

The strength of evidence is graded as insufficient because of lack of RCT data.

#### CAS and medical therapy versus CEA and medical therapy (Key Question 3)

One quality-A RCT and two quality-B RCTs reported data on the risk of adverse events, including any periprocedural stroke, death, or MI (or combinations thereof) with CAS as compared with CEA. No statistically significant difference in the risk of periprocedural adverse events was found between the two interventions. The strength of evidence is graded as insufficient because between-trial comparisons were not possible, as there was extreme clinical heterogeneity. In addition, for clinical outcomes, the observed point estimates were in opposite directions (periprocedural stroke or death were nonsignificantly higher in the CAS group, and periprocedural MI events were nonsignificantly higher in the CEA group).

##### Any periprocedural stroke

CREST reported a statistically nonsignificant increase in the occurrence of any periprocedural stroke in CAS as compared with CEA (HR = 1.88, 95% CI = 0.79, 4.42). Similar results were reported in the SAPPHIRE trial, with a nonsignificant increase in the risk of any periprocedural stroke (RR = 1.54, 95% CI = 0.44, 5.31) or periprocedural ipsilateral stroke (RR = 1.71, 95% CI = 0.42, 6.99) with CAS as compared with CEA. No cerebrovascular events occurred in the Brooks 2004 trial.

##### Periprocedural death

Two RCTs (CREST and SAPPHIRE) reported this outcome. In CREST, there was no periprocedural death in the two treatment groups. The SAPPHIRE trial reported a nonsignificant increase in the risk of periprocedural death in CAS as compared with CEA (RR = 2.05, 95% CI = 0.18, 22.3), but the wide confidence interval indicates great uncertainty.

##### Periprocedural MI

Two RCTs (CREST and SAPPHIRE) reported a nonsignificantly reduced risk of periprocedural MI with CAS as compared with CEA. CREST reported a nonsignificantly decreased occurrence of periprocedural MI in CAS as compared with CEA (HR = 0.55, 95% CI = 0.22, 1.38). Similar results were reported in the SAPPHIRE trial, with a nonsignificant decrease in the risk of periprocedural MI (RR = 0.38, 95% CI = 0.10, 1.41).

##### Periprocedural composite outcome of any stroke, MI, or death

Two RCTs (CREST and SAPPHIRE) examined the composite outcome of any stroke, MI, or death. CREST found no difference in the risk of this composite outcome between CAS and CEA (adjusted HR = 1.02, 95% CI = 0.55, 1.86). According to the reported events in the published paper of the SAPPHIRE trial, there was a nonsignificantly decreased risk of the composite outcome with CAS as compared with CEA (RR = 0.51, 95% CI = 0.19, 1.32). We observed minor inconsistencies in the numbers of reported events for this outcome between the published paper and the data available from the FDA.

##### Periprocedural composite outcome of any stroke or death

Two RCTs (CREST and SAPPHIRE) examined the composite outcome of any stroke or death. CREST reported a nonsignificantly increased risk of this composite outcome in CAS as compared with CEA (adjusted HR = 1.88, 95% CI = 0.79, 4.42). On the basis of the reported numbers of events in the FDA report of the SAPPHIRE trial, a nonsignificantly increased risk of the composite outcome with CAS as compared with CEA was estimated (RR = 1.44, 95% CI = 0.47, 4.40).

##### Periprocedural cranial nerve palsy

In a meta-analysis of the two RCTs (CREST and Brooks 2004), a statistically significant reduction in the risk of cranial nerve palsy with CAS over CEA was found (summary RR = 0.06, 95% CI = 0.01, 0.31), without statistical heterogeneity (I^2^ =0.0%, P=0.48).

##### Periprocedural bleeding complications

CREST reported no differences in the risk of hematoma or bleeding between CAS and CEA.

## Applicability

Studies of medical therapy alone, specifically studies with a recruitment closure year between 2000 and 2010, were deemed applicable to contemporary clinical practice. Data for subgroup analysis of baseline features such as contralateral CEA and clinical or anatomic features of carotid artery stenosis (> 70 percent) were available. However, no separate data for subgroup analysis according to the age categories (≥ 65 years or ≥ 80 years) were available. In addition, no separate subgroup data by sex or baseline comorbid medical conditions were available.

Trials comparing CEA with medical therapy alone provided specific data for all subgroups of interest. In these trials, at randomization, patients with asymptomatic carotid stenosis did not receive what is currently considered best medical therapy, including the use of statins and specific targets for the management of hypertension and diabetes. Thus the results of these older CEA trials may not be applicable or relevant to contemporary clinical practice. There were insufficient data reported for the comparison of CAS with medical therapy alone and therefore, the applicability was not assessed. At least one of the trials comparing CAS with CEA reported data relevant to all subgroups of interest. The patient-selection process in the SAPPHIRE trial, in which almost half of potentially eligible patients were not randomized but rather were included in a stenting registry, poses significant limitations in assessing the applicability of the study results. Similar patient-selection issues were reported in CREST prolonging the enrollment phase, in which eligible patients were enrolled into one of several stent registries. All trials were conducted at tertiary medical centers; thus, their results may not be generalizable to community settings.

## Conclusions

The goal of management of asymptomatic carotid stenosis is to decrease the risk of stroke and stroke-related deaths. Our review of therapeutic strategies in patients with asymptomatic carotid stenosis indicates that there has been a significant reduction in the incidence of ipsilateral stroke over time with medical therapy alone. Our subgroup analysis shows that between the year 2000 and 2010, the current best medical therapy can reduce the risk of ipsilateral stroke to nearly 1 percent per year of followup. In addition, use of statins by ≥ 25 percent (vs. < 25 percent) of the study population and use of antiplatelet therapy by ≥ 50 percent (vs. < 50 percent) of the study population was associated with significantly decreased rates of ipsilateral stroke in a few studies that reported this information.

Older trials comparing CEA with medical therapy demonstrate a reduction in the occurrence of stroke. This observed reduction reflects the low perioperative complication rate of < 3 percent achieved in ACAS and ACST. In these trials, surgeons were selected on the basis of their past operative experience and the surgeries were conducted in tertiary care centers. Thus, to reduce any future stroke-related events invasive procedures must carry an exceedingly low risk of periprocedural adverse events, which may be difficult to achieve in routine clinical settings. In view of recent advances in medical therapy, the applicability or generalizability of the older CEA trial results to contemporary clinical practice requires careful interpretation. There is no randomized trial comparing CAS with medical therapy alone.

One recent large trial (CREST) reported higher rates of postprocedural ipsilateral stroke (including any periprocedural stroke) and its composite primary endpoint in the CAS, as compared with CEA, but this did not reach statistical significance in patients with asymptomatic carotid stenosis. The CREST and the SAPPHIRE trials randomized patients with symptomatic and asymptomatic carotid stenosis stratified according to symptom status. Therefore, the treatment assignment was randomized among the subgroup of patients with asymptomatic carotid stenosis. However, neither trial was powered to detect a significant difference in the primary composite endpoint among subgroups of patients with asymptomatic carotid stenosis. The failure to find a significant difference does not rule out the possibility that real difference exists between the intervention modalities tested.

In this review, we examined both older studies and more recent publications. Also in contrast to prior reviews, we examined nonrandomized studies conducted in real-world settings to evaluate the effectiveness of therapeutic strategies. Our review concludes that future trials should evaluate whether patients with asymptomatic carotid stenosis with >70 percent stenosis treated by current best medical therapy will derive additional benefit from invasive carotid revascularization procedures. Some limitations of this review directly reflect limitations of the data available in primary studies. The inclusion of populations in the studies was heterogeneous and reflects a lack of consensus in defining patients with asymptomatic carotid stenosis. The trials presented survival data for different outcomes, precluding us from conducting meta-analyses that would account for differential followup durations. The CAS trials included populations with extreme clinical heterogeneity and therefore were not combined in meta-analyses. Finally, our analyses and results were based on study-level data, but not patient-level data.

Patients with asymptomatic carotid stenosis are at an increased risk of future cerebrovascular events. Any expected benefits of an intervention depend on the reduction of the risk of future stroke-related events. Achieving this by medical therapy alone would allow patients to avoid the potential complications of invasive interventional procedures. Our review of medical cohort studies indicates that all patients with asymptomatic stenosis are likely to benefit from current best medical therapy alone. Recent observational studies suggest that there are methods to identify the high-risk group of patients with asymptomatic carotid stenosis who may benefit from invasive interventional procedures. Future trials should focus not only on whether CAS is equivalent or superior to CEA, but also on whether an invasive interventional procedure is likely to translate into any significant benefit to the patient treated with current best medical therapy.