# Abbreviations and Acronyms

ACAS: Asymptomatic Carotid Atherosclerosis Study
ACE-I: Angiotensin-converting enzyme inhibitor
ACR: American College of Radiology
ACST: Asymptomatic Carotid Surgery Trial
AHA: American Heart Association
ASA: American Stroke Association
CAD: Coronary artery disease
CaRESS: Carotid Revascularization Using Endarterectomy or Stenting Systems
CAS: Carotid angioplasty and stenting
CASANOVA: Carotid Artery Stenosis with Asymptomatic Narrowing: Operation versus Aspirin
CEA: Carotid endarterectomy
CI: Confidence interval
CREST: Carotid Revascularization Endarterectomy Versus Stenting Trial
CTA: Computed tomography angiography
CVD: Cardiovascular disease
DSA: Digital subtraction angiography
DUS: Doppler ultrasound
ECST: European Carotid Surgery Trial
HR: Hazard ratio
ICA: Internal carotid artery
ICAVL: Intersocietal Commission for the Accreditation of Vascular Laboratories
MI: Myocardial infarction
MRA: Magnetic resonance angiography
NASCET: North American Symptomatic Carotid Endarterectomy Trial
OPG: Ocular pneumoplethysmography
RCT: Randomized controlled trial
RR: Relative risk
SAPPHIRE: Stenting and Angioplasty with Protection in Patients at High Risk for Endarterectomy
SVS-VR: Society for Vascular Surgery–Vascular Registry
TIA: Transient ischemic attack
VA: Veterans Affairs