# Acknowledgements

The authors of this report thank other members of the Tufts Evidence-based Practice Center (EPC), Ethan Balk MD MPH and Thomas A Trikalinos MD PhD, for helpful suggestions on a draft version of this report. We thank Jenny Lamont, MS, for editing a draft and final version of this report.