# Discussion

## Summary of findings

Our systematic review indicates that the summary incidence rate of ipsilateral stroke was 1.59 percent per year in quality-A and -B studies among patients with asymptomatic carotid stenosis who were treated with medical therapy alone. There is moderate strength of evidence that medical therapy alone can reduce the incidence rate of ipsilateral stroke over time. Our review of RCTs demonstrates a significant reduction in the risk of ipsilateral stroke or any stroke with CEA and medical therapy compared with medical therapy alone. However, the strength of the available evidence is graded as moderate for this comparison because these trials were conducted from the 1990's through early 2000 and thus, their results may not translate to contemporary clinical practice. The strength of evidence is graded as insufficient because of lack of RCTs comparing CAS and medical therapy with medical therapy alone. Our review of RCTs comparing CAS and medical therapy with CEA and medical therapy found no statistically significant differences between the two interventional modalities. However, across two trials, the clinical heterogeneity and the observed effect estimates were in opposite directions (as evidenced in individual forest plots) and the summary estimates were in opposite directions across periprocedural outcomes. Therefore, the strength of evidence is graded as insufficient.

### Medical therapy alone

Our meta-analysis of quality-A and quality-B prospective studies involving medical therapy alone for the ipsilateral asymptomatic carotid artery of interest showed that the summary incidence rate of ipsilateral stroke was relatively low, which suggests that asymptomatic patients can benefit from either CEA or CAS in addition to medical therapy only if these interventions are performed with very low periprocedural risk. It is important to note that in the majority of the older studies included in this analysis the enrolled patients did not receive what is currently considered intensive medical therapy, which may involve the use of vascular protective agents, such as dual antiplatelet agents, ACE-inhibitors, and statins as is evidenced in the treatment of hypertension, diabetes, and hyperlipidemia – all of which have aggressive treatment goals. When the analysis was restricted to the more recent studies (with recruitment of patients between 2000 and 2010), the summary incidence rate of ipsilateral stroke was 1.1 percent per year, much lower than published event rates before 2000 (2.3 percent per year). In a subgroup meta-analysis stratified by the reported use of statins in each study, it was shown that studies in statins were used by more than 25 percent of the study population had a significantly decreased rate of ipsilateral stroke compared with use of statins by less than 25 percent of the study population. Additional evidence from meta-regression analyses indicates a reduction in the rates of ipsilateral stroke, which showed that there is a statistically significant reduction in the incidence rate of ipsilateral stroke (and ipsilateral stroke or TIA) over time.

This significant reduction in the rate of ipsilateral events is in agreement with a recent systematic review that examined a smaller number of studies (n=11) by using a weighted linear regression model analysis.13 In comparison to this review, which excluded studies with <100 participants, our review used a threshold of at least 30 participants in each study resulting in more heterogeneous, but larger number of studies (n=41 studies in total). Furthermore, for the analysis of these data we employed a formal meta-regression model with the Poisson likelihood, which is more appropriate for the analysis of such rare events.

In contrast, we found no significant effect of time for any territory cerebrovascular outcomes (any stroke and any stroke or TIA). This finding contradicts to a previous analysis conducted by a recent systematic review, which reported significant reduction in the published rates of any stroke and any stroke or TIA.13 This apparent discrepancy between our results and the analysis by the previous systematic review may stem from differences in our inclusion criteria. The previous systematic review included studies reporting any territory outcomes only if these studies provided data on ipsilateral stroke events as well, whereas our review included studies with any territory outcome data, irrespective of whether ipsilateral outcomes were provided. Thus, the two systematic reviews are not directly comparable. When we conducted a sensitivity analysis of any territory stroke by including only those studies that reported ipsilateral events, then this demonstrated a significant reduction of the incidence rates of any stroke. Our all-inclusive analysis of studies for any stroke events did not show the same reduction pattern, which may be due to potential differences in the ascertainment of outcomes between studies that did and did not report ipsilateral stroke, e.g. ascertainment of any territory stroke being more sensitive in studies that reported the outcome of ipsilateral stroke as well. Furthermore, limiting our analyses to quality-A and -B studies, significant effect of time (older vs. newer studies) was detected for any territory stroke and any stroke or TIA.

In this review, subgroup analysis of medically treated patients by degree of stenosis showed that the populations with >70 percent carotid stenosis did not have a significantly higher summary incidence rate of ipsilateral stroke compared with the subgroup of 50-70 percent stenosis. Nevertheless, severity of stenosis in medically-treated patients was associated with higher summary incidence rates for all other cerebrovascular outcomes (ipsilateral stroke or TIA, any stroke, and any stroke or TIA) indicating that severity of stenosis may be a surrogate marker of cerebrovascular disease.

In summary, there is moderate strength of evidence that the use of intensive systemic medical therapy in the context of vascular diseases can reduce ipsilateral stroke, any stroke, and death.

### CEA and medical therapy versus medical therapy alone

It is important to note that three RCTs were conducted during the 1990s through early 2000. These trials used ‘standard of care’ medical therapy that was considered appropriate for management of patients with asymptomatic carotid stenosis during that period. The medical therapy group at randomization did not receive what is currently considered as optimal medical therapy, including the use of statins. Thus, their stroke event rate may be higher than currently seen in optimally treated medical patients. The reduction of ipsilateral stroke with CEA and medical therapy observed in these RCTs mostly reflects the low perioperative adverse event rate (< 3 percent) in the ACAS and the ACST trials. The surgeons in these trials were selected based on their past operative experience and the surgeries were conducted in tertiary care centers. Such a low rate of adverse events may be difficult to achieve in routine clinical settings.99 Given the recent advances in medical therapy of vascular diseases, the findings of these RCTs may not be generalizable to contemporary clinical practice. The ACAS trial showed significant reduction in the risk of ipsilateral stroke (including perioperative stroke or death), while ACST at 10-year followup showed a reduction in the risk of any nonperioperative stroke on either carotid artery territory. The use of lipid-lowering therapy was much more prevalent during the later years of followup in ACST trial; the absolute benefits achieved from successful CEA were much smaller in those patients on lipid-lowering therapy as compared with those who were not on lipid-lowering therapy. In contrast to the RCTs, the nonrandomized comparative studies showed heterogeneous results without significant difference between the two interventions.

### CAS and medical therapy versus medical therapy alone

There was paucity of randomized data for the comparison of CAS and medical therapy with medical therapy alone. Of the two eligible studies that were reviewed, only one nonrandomized comparative study reported long-term adverse clinical outcomes comparing patients receiving CAS and medical therapy with medical therapy alone. This study did not report the outcome of ipsilateral stroke, but reported a significantly decreased risk of any stroke or death in the CAS group compared with medical therapy group.

### CAS and medical therapy versus CEA and medical therapy

Despite showing no significant differences in the efficacy of CAS and medical therapy compared with CEA and medical therapy for the long-term adverse outcomes by two RCTs, the effect estimates for long-term data were in opposite directions, as evidenced in forest plots, and were in opposite directions across trials for periprocedural outcomes..

The medical and vascular interventions used in the CREST and SAPPHIRE trials were similar; the majority of patients received antiplatelet regimens and underwent stent implantation with the use of embolic protection devices. However, there was considerable clinical heterogeneity in the patients enrolled in these trials. The SAPPHIRE included patients with anatomically more advanced stenosis and those at high-risk for complications with CEA. About 20 percent of patients included in this trial also had a history of a prior CEA in their carotid artery of interest, and were thus undergoing intervention in previously operated arteries. In contrast, CREST included low-risk patients with moderate stenosis. The clinical differences between these two trial populations may account for the opposite direction in terms of the point estimates of relative risks of ipsilateral stroke, favoring CAS in the SAPPHIRE trial and favoring CEA in the CREST. In addition, different types of stents were used in these trials.

The CREST and SAPPHIRE trials enrolled both symptomatic and asymptomatic patients with randomization stratified according to symptomatic status. Therefore, the interventions were randomly assigned among asymptomatic subgroup. However, neither trial was powered to detect differences in the primary composite endpoint among subgroups of patients with asymptomatic carotid stenosis. The failure to find statistically significant differences does not rule out the possibility that real differences exist between the interventions. In addition to the inadequately powered asymptomatic subgroups, no significant differences between CAS and CEA demonstrated in these two RCTs may also be a reflection of including MIs in the composite primary endpoint. In both trials, dual antiplatelet therapy was offered only to the CAS group. However, in the CREST, patients in the CEA group experienced more MIs in the periprocedural period compared to the CAS group, but an increased occurrence of more stroke events in the CAS group. In a secondary outcome analysis excluding MIs, the CAS group had 86 percent increase in the relative hazards of periprocedural stroke or death or postprocedural ipsilateral stroke, although this increase did not reach statistical significance (P=0.07). The use of dual antiplatelet therapy during CEA is an area of ongoing research that may further reduce adverse event rates with CEA. Finally, the patient selection process applied in the SAPPHIRE trial, in which almost half of potentially eligible patients were not randomized but were included in a stenting registry, poses significant limitations in assessing the applicability of the study results with respect to identifying patients in clinical practice who would be similar to the ones that underwent randomization.

Regarding within 30-day outcomes, in individual trials, there was no statistically significant difference in periprocedural cardiovascular adverse event rates between CAS and CEA. On the contrary, synthesis of results from nonrandomized studies using administrative or clinical datasets showed that CAS was associated with significantly increased risk of periprocedural stroke and periprocedural death as compared with CEA. These estimates of increased risk are derived from large sample sizes and thus have robust statistical support. However, inferences drawn from administrative datasets need caution. These studies are vulnerable to selection bias, ascertainment bias, and confounding. Of particular concern is confounding by indication, that is, patients who are selected to undergo CAS may be based on the perceived surgical risks. Thus, in these observational studies, patients who undergo CAS may not be comparable with patients who undergo CEA, in particular for the outcome of periprocedural adverse events.

### Context of findings (Comparison with recent reviews)

A published meta-analysis of RCTs evaluated patients with both symptomatic and asymptomatic carotid stenosis and found no significant differences in ipsilateral stroke or composite endpoints of ipsilateral stroke between the two interventions in a stratified analysis of the two RCTs in patients with asymptomatic carotid stenosis (CREST and SAPPHIRE).100 However, to the best of our knowledge, observational data for the efficacy of CAS compared with CEA have not been considered in previous systematic reviews.

Recent guidelines state that it is reasonable to perform prophylactive CEA or CAS in the select group of patients with asymptomatic carotid stenosis with >70 percent stenosis. They recommend that such a decision should incorporate patient preferences, ascertained by a thorough discussion of the risks and benefits of the procedure.

In this review, we examine both older studies and more recent publications. Also in contrast to prior reviews, we examined nonrandomized studies conducted in real-world settings to evaluate the effectiveness of therapeutic strategies. Our review concludes that future trials should evaluate whether patients with asymptomatic carotid stenosis with >70 percent stenosis treated by current best medical therapy will derive additional benefit from invasive carotid revascularization procedures.

### Limitations

The limitations of this review directly reflect limitations of the data available in primary studies. The inclusion of populations in the studies was heterogeneous and reflects a lack of consensus in defining patients with asymptomatic carotid stenosis. The trials presented survival data for different outcomes, precluding us from conducting meta-analyses that would account for differential followup durations. The CAS trials included populations with extreme clinical heterogeneity and therefore were not combined in meta-analyses.

## Conclusions

The goal of management of asymptomatic carotid stenosis is to decrease the risk of stroke and stroke-related deaths. Our review of therapeutic strategies in patients with asymptomatic carotid stenosis indicates that there has been a significant reduction in the incidence of ipsilateral stroke over time with medical therapy alone. Our subgroup analysis shows that between the year 2000 and 2010, the current best medical therapy can reduce the risk of ipsilateral stroke to nearly 1 percent per year of followup. Older trials comparing CEA with medical therapy demonstrate a reduction in the occurrence of stroke. This observed reduction reflects the low perioperative adverse event rate of < 3 percent achieved in ACAS and ACST. In these trials, surgeons were selected on the basis of their past operative experience and the surgeries were conducted in tertiary care centers. Thus, to reduce any future stroke-related events invasive procedures must carry an exceedingly low risk of periprocedural adverse events, which may be difficult to achieve in routine clinical settings. In view of recent advances in medical therapy, the applicability or generalizability of the older CEA trial results to contemporary clinical practice requires careful interpretation. There is no randomized trial comparing CAS with medical therapy alone. One recent large trial (CREST) reported higher rates of postprocedural ipsilateral stroke (including any periprocedural stroke) and its composite primary endpoint in the CAS, as compared with CEA, but this did not reach statistical significance in patients with asymptomatic carotid stenosis. The CREST and SAPPHIRE trials randomized patients with symptomatic and asymptomatic carotid stenosis stratified according to symptom status. Therefore, the treatment assignment was randomized among the subgroup of patients with asymptomatic carotid stenosis. However, neither trial was powered to detect a significant difference in the primary composite endpoint among subgroups of patients with asymptomatic carotid stenosis. The failure to find a significant difference does not rule out the possibility that real difference exists between the intervention modalities tested. Patients with asymptomatic carotid stenosis are at an increased risk of future cerebrovascular events. Any expected benefits of an intervention depend on the reduction of the risk of future stroke-related events. Achieving this by medical therapy alone would allow patients to avoid the potential complications of invasive interventional procedures. Our review indicates that all patients with asymptomatic stenosis are likely to benefit from current best medical therapy alone. Recent observational studies suggest that there are methods to identify the high-risk group of patients with asymptomatic carotid stenosis who may benefit from invasive interventional procedures.49,54,101 Future trials should focus not only on whether CAS is equivalent or superior to CEA, but also on whether an invasive interventional procedure is likely to translate into any significant benefit to the patient treated by current best medical therapy.

## Future research

- In patients with asymptomatic carotid stenosis, trials evaluating current best medical therapy with or without invasive interventional approaches are needed.
- Proper analyses of nonrandomized comparative studies using either propensity score-matched analyses or instrumental variable analyses are needed.
- Collaborative individual patient-level meta-analyses identifying subpopulations that will benefit from different treatment strategies are needed.
- Future research is needed to evaluate the functional significance of periprocedural MI in the long-term prognosis of those undergoing invasive interventional approaches, which are aimed to reduce stroke outcomes.
- Creation of registries to include quality observational data of medically managed patients with asymptomatic carotid stenosis is needed. This will aid in risk stratification of patients who will benefit from medical therapy alone.
- Explorative analysis of large prospectively collected data is needed to aid in risk stratification of patients, who will benefit from medical therapy alone.
- Explorative analysis of large administrative data sets is needed to aid in risk stratification of patients who will have reduced periprocedural events in those undergoing interventional procedures.
- Evaluation of the role of predictive effects of the following imaging parameters are needed: a) silent infarction on baseline computed tomography or magnetic resonance imaging (MRI), b) spontaneous embolization on transcranial Doppler, c) computerized ultrasound plaque analysis, and d) evidence of intraplaque haemorrhage on MRI.
- Conducting value of information analysis with an aim to reduce uncertainty in a decision context is needed.