# List of included studies

1 No Authors listed. Carotid surgery versus medical therapy in asymptomatic carotid stenosis. The CASANOVA Study Group. Stroke. 1991;22:1229-35. [pmid: 1926232].
2 No Authors listed. Results of a randomized controlled trial of carotid endarterectomy for asymptomatic carotid stenosis. Mayo Asymptomatic Carotid Endarterectomy Study Group. Mayo Clinic Proceedings. 1992;67:513-18. [pmid: 1434877].
3 No Authors listed. Endarterectomy for asymptomatic carotid artery stenosis. Executive Committee for the Asymptomatic Carotid Atherosclerosis Study. JAMA. 1995;273:1421-28. [pmid: 7723155].
4 No Authors listed. Risk of stroke in the distribution of an asymptomatic carotid artery. The European Carotid Surgery Trialists Collaborative Group. Lancet. 1995;345:209-12. [pmid: 7823712].
5 Abbott AL, Chambers BR, Stork JL, Levi CR, Bladin CF, Donnan GA. Embolic signals and prediction of ipsilateral stroke or transient ischemic attack in asymptomatic carotid stenosis: a multicenter prospective cohort study. Stroke. 2005;36:1128-33. [pmid: 15879327].
6 AbuRahma AF, Metz MJ, Robinson PA. Natural history of >or =60% asymptomatic carotid stenosis in patients with contralateral carotid occlusion. Annals of Surgery. 2003;238:551-61. [pmid: 14530726].
7 AbuRahma AF, Cook CC, Metz MJ, Wulu JT Jr., Bartolucci A. Natural history of carotid artery stenosis contralateral to endarterectomy: results from two randomized prospective trials. Journal of Vascular Surgery. 2003;38:1154-61. [pmid: 14681599].
8 Aichner FT, Topakian R, Alberts MJ, Bhatt DL, Haring HP, Hill MD, et al. High cardiovascular event rates in patients with asymptomatic carotid stenosis: the REACH Registry. European Journal of Neurology. 2009;16:902-8. [pmid: 19473362].
9 Anderson DC, Kappelle LJ, Eliasziw M, Babikian VL, Pearce LA, Barnett HJ. Occurrence of hemispheric and retinal ischemia in atrial fibrillation compared with carotid stenosis. Stroke. 2002;33:1963-67. [pmid: 12154246].
10 Ballotta E, Da G G, Meneghetti G, Barbon B, Militello C, Baracchini C. Progression of atherosclerosis in asymptomatic carotid arteries after contralateral endarterectomy: a 10-year prospective study. Journal of Vascular Surgery. 2007;45:516-22. [pmid: 17275244].
11 Bock RW, Gray-Weale AC, Mock PA, App SM, Robinson DA, Irwig L, et al. The natural history of asymptomatic carotid artery disease. Journal of Vascular Surgery. 1993;17:160-169. [pmid: 8421333].
12 Bogousslavsky J, Despland PA, Regli F. Asymptomatic tight stenosis of the internal carotid artery: long-term prognosis. Neurology. 1986;36:861-63. [pmid: 3703297].
13 Dick P, Sherif C, Sabeti S, Amighi J, Minar E, Schillinger M. Gender differences in outcome of conservatively treated patients with asymptomatic high grade carotid stenosis. Stroke. 2005;36:1178-83. [pmid: 15890998].
14 Ellis MR, Franks PJ, Cuming R, Powell JT, Greenhalgh RM. Prevalence, progression and natural history of asymptomatic carotid stenosis: is there a place for carotid endarterectomy?. European Journal of Vascular Surgery. 1992;6:172-77. [pmid: 1572457].
15 Goessens BM, Visseren FL, Kappelle LJ, Algra A, van der GY. Asymptomatic carotid artery stenosis and the risk of new vascular events in patients with manifest arterial disease: the SMART study. Stroke. 2007;38:1470-1475. [pmid: 17363718].
16 Gronholdt ML, Nordestgaard BG, Schroeder TV, Vorstrup S, Sillesen H. Ultrasonic echolucent carotid plaques predict future strokes. Circulation. 2001;104:68-73. [pmid: 11435340].
17 Gur AY, Bova I, Bornstein NM. Is impaired cerebral vasomotor reactivity a predictive factor of stroke in asymptomatic patients?. Stroke. 1996;27:2188-90. [pmid: 8969778].
18 Halliday A, Mansfield A, Marro J, Peto C, Peto R, Potter J, et al. Prevention of disabling and fatal strokes by successful carotid endarterectomy in patients without recent neurological symptoms: randomised controlled trial. Lancet. 2004;363:1491-502. [pmid: 15135594].
19 Halliday A, Harrison M, Hayter E, Kong X, Mansfield A, Marro J, et al. 10-year stroke prevention after successful carotid endarterectomy for asymptomatic stenosis (ACST-1): a multicentre randomised trial. Lancet. 2010;376:1074-84. [pmid: 20870099].
20 Hennerici M, Hulsbomer HB, Hefter H, Lammerts D, Rautenberg W. Natural history of asymptomatic extracranial arterial disease. Results of a long-term prospective study. Brain. 1987;110:777-91. [pmid: 3580834].
21 Hobson RW, Weiss DG, Fields WS, Goldstone J, Moore WS, Towne JB, et al. Efficacy of carotid endarterectomy for asymptomatic carotid stenosis. The Veterans Affairs Cooperative Study Group. New England Journal of Medicine. 1993;328:221-27. [pmid: 8418401].
22 Inzitari D, Eliasziw M, Gates P, Sharpe BL, Chan RK, Meldrum HE, et al. The causes and risk of stroke in patients with asymptomatic internal-carotid-artery stenosis. North American Symptomatic Carotid Endarterectomy Trial Collaborators. New England Journal of Medicine. 2000;342:1693-700. [pmid: 10841871].
23 Johnson BF, Verlato F, Bergelin RO, Primozich JF, Strandness E Jr. Clinical outcome in patients with mild and moderate carotid artery stenosis. Journal of Vascular Surgery. 1995;21:120-126. [pmid: 7823350].
24 Johnson JM, Kennelly MM, DeCesare D, Morgan S, Sparrow A. Natural history of asymptomatic carotid plaque. Archives of Surgery. 1985;120:1010-1012. [pmid: 3896195].
25 Kakkos SK, Nicolaides A, Griffin M, Sabetai M, Dhanjil S, Thomas DJ, et al. Factors associated with mortality in patients with asymptomatic carotid stenosis: results from the ACSRS Study. International Angiology. 2005;24:221-30. [pmid: 16158030].
26 Langsfeld M, Gray-Weale AC, Lusby RJ. The role of plaque morphology and diameter reduction in the development of new symptoms in asymptomatic carotid arteries. Journal of Vascular Surgery. 1989;9:548-57. [pmid: 2651727].
27 Levien LJ, Fritz VU, Lithgow-Jolly P. The natural history of asymptomatic carotid disease. A preliminary report. South African Journal of Surgery. 1984;22:249-53. [pmid: 6523303].
28 Liapis CD, Kakisis JD, Kostakis AG. Carotid stenosis: factors affecting symptomatology. Stroke. 2001;32:2782-86. [pmid: 11739973].
29 Longstreth WT Jr., Shemanski L, Lefkowitz D, O'Leary DH, Polak JF, Wolfson SK Jr. Asymptomatic internal carotid artery stenosis defined by ultrasound and the risk of subsequent stroke in the elderly. The Cardiovascular Health Study. Stroke. 1998;29:2371-76. [pmid: 9804651].
30 Mackey AE, Abrahamowicz M, Langlois Y, Battista R, Simard D, Bourque F, et al. Outcome of asymptomatic patients with carotid disease. Asymptomatic Cervical Bruit Study Group. Neurology. 1997;48:896-903. [pmid: 9109874].
31 Mansour MA, Littooy FN, Watson WC, Blumofe KA, Heilizer TJ, Steffen GF, et al. Outcome of moderate carotid artery stenosis in patients who are asymptomatic. Journal of Vascular Surgery. 1999;29:217-25. [pmid: 9950980].
32 Markus HS, King A, Shipley M, Topakian R, Cullinane M, Reihill S, et al. Asymptomatic embolisation for prediction of stroke in the Asymptomatic Carotid Emboli Study (ACES): a prospective observational study. Lancet Neurol. 2010;9:663-71. [pmid: 20554250].
33 Marquardt L, Geraghty OC, Mehta Z, Rothwell PM. Low risk of ipsilateral stroke in patients with asymptomatic carotid stenosis on best medical treatment: a prospective, population-based study. Stroke. 2010;41:e11-e17. [pmid: 19926843].
34 Nicolaides AN, Kakkos SK, Griffin M, Sabetai M, Dhanjil S, Tegos T, et al. Severity of asymptomatic carotid stenosis and risk of ipsilateral hemispheric ischaemic events: results from the ACSRS study. European Journal of Vascular & Endovascular Surgery. 2005;30:275-84. [pmid: 16130207].
35 Norris JW, Zhu CZ, Bornstein NM, Chambers BR. Vascular risks of asymptomatic carotid stenosis. Stroke. 1991;22:1485-90. [pmid: 1962321].
36 Sabeti S, Schlager O, Exner M, Mlekusch W, Amighi J, Dick P, et al. Progression of carotid stenosis detected by duplex ultrasonography predicts adverse outcomes in cardiovascular high-risk patients. Stroke. 2007;38:2887-94. [pmid: 17885257].
37 Satiani B, Porter RM Jr. The influence of contralateral disease on the natural history of nonoperated significant carotid stenosis. Annals of Vascular Surgery. 1990;4:313-17. [pmid: 2364044].
38 Satiani B, Chen TY, Shook L, Finnie K. Contralateral disease progression after carotid endarterectomy. Surgery. 1993;114:46-51. [pmid: 8356526].
39 Siebler M, Nachtmann A, Sitzer M, Rose G, Kleinschmidt A, Rademacher J, et al. Cerebral microembolism and the risk of ischemia in asymptomatic high-grade internal carotid artery stenosis. Stroke. 1995;26:2184-86. [pmid: 7482670].
40 Silvestrini M, Vernieri F, Pasqualetti P, Matteis M, Passarelli F, Troisi E, et al. Impaired cerebral vasoreactivity and risk of stroke in patients with asymptomatic carotid artery stenosis. JAMA. 2000;283:2122-27. [pmid: 10791504].
41 Spence JD, Tamayo A, Lownie SP, Ng WP, Ferguson GG. Absence of microemboli on transcranial Doppler identifies low-risk patients with asymptomatic carotid stenosis. Stroke. 2005;36:2373-78. [pmid: 16224084].
42 Spence JD, Coates V, Li H, Tamayo A, Munoz C, Hackam DG, et al. Effects of intensive medical therapy on microemboli and cardiovascular risk in asymptomatic carotid stenosis. Archives of Neurology. 2010;67:180-186. [pmid: 20008646].
43 Takahashi W, Ohnuki T, Ide M, Takagi S, Shinohara Y. Stroke risk of asymptomatic intra- and extracranial large-artery disease in apparently healthy adults. Cerebrovascular Diseases. 2006;22:263-70. [pmid: 16788300].
44 Takaya N, Yuan C, Chu B, Saam T, Underhill H, Cai J, et al. Association between carotid plaque characteristics and subsequent ischemic cerebrovascular events: a prospective assessment with MRI--initial results. Stroke. 2006;37:818-23. [pmid: 16469957].
45 Bosiers M, Peeters P, Deloose K, Verbist J, Sprouse RL. Selection of treatment for patients with carotid artery disease: medication, carotid endarterectomy, or carotid artery stenting. Vascular. 2005;13:92-97. [pmid: 15996363].
46 Caracci BF, Zukowski AJ, Hurley JJ, Naunheim KS, Auer AI. Asymptomatic severe carotid stenosis. Journal of Vascular Surgery. 1989;9:361-66. [pmid: 2645445].
47 Hertzer NR, Flanagan RA Jr., Beven EG, O'Hara PJ. Surgical versus nonoperative treatment of asymptomatic carotid stenosis. 290 patients documented by intravenous angiography. Annals of Surgery. 1986;204:163-71. [pmid: 3527089].
48 Libman RB, Sacco RL, Shi T, Correll JW, Mohr JP. Outcome after carotid endarterectomy for asymptomatic carotid stenosis. Surgical Neurology. 1994;41:443-49. [pmid: 8059320].
49 Poulias GE, Doundoulakis N, Skoutas B, Haddad H, Karkanias G, Papadakis E. Carotid artery surgery and the principle of prophylaxis: recurrence in operated and nonoperated patients. Cardiovascular Surgery. 1994;2:586-91. [pmid: 7820518].
50 Sherif C, Dick P, Sabeti S, Mlekusch W, Amighi J, Ahmadi R, et al. Neurological outcome of conservative versus endovascular treatment of patients with asymptomatic high-grade carotid artery stenosis: a propensity score-adjusted analysis. Journal of Endovascular Therapy: Official Journal of the International Society of Endovascular Specialists. 2005;12:145-55. [pmid: 15823061].
51 Brott TG, Hobson RW, Howard G, Roubin GS, Clark WM, Brooks W, et al. Stenting versus endarterectomy for treatment of carotid-artery stenosis. New England Journal of Medicine. 2010;363:11-23. [pmid: 20505173].
52 Gurm HS, Yadav JS, Fayad P, Katzen BT, Mishkel GJ, Bajwa TK, et al. Long-term results of carotid stenting versus endarterectomy in high-risk patients. New England Journal of Medicine. 2008;358:1572-79. [pmid: 18403765].
53 Yadav JS, Wholey MH, Kuntz RE, Fayad P, Katzen BT, Mishkel GJ, et al. Protected carotid-artery stenting versus endarterectomy in high-risk patients. New England Journal of Medicine. 2004;351:1493-501. [pmid: 15470212].
54 Brooks WH, McClure RR, Jones MR, Coleman TL, Breathitt L. Carotid angioplasty and stenting versus carotid endarterectomy for treatment of asymptomatic carotid stenosis: a randomized trial in a community hospital. Neurosurgery. 2004;54:318-24. [pmid: 14744277].
55 CaRESS Steering Committee. Carotid Revascularization Using Endarterectomy or Stenting Systems (CaRESS) phase I clinical trial: 1-year results. Journal of Vascular Surgery. 2005;42:213-19. [pmid: 16102616].
56 Zarins CK, White RA, Diethrich EB, Shackelton RJ, Siami FS, CaRESS Steering Committee and CaRESS Investigators. Carotid revascularization using endarterectomy or stenting systems (CaRESS): 4-year outcomes. Journal of Endovascular Therapy: Official Journal of the International Society of Endovascular Specialists. 2009;16:397-409. [pmid: 19702339].
57 Marine LA, Rubin BG, Reddy R, Sanchez LA, Parodi JC, Sicard GA. Treatment of asymptomatic carotid artery disease: similar early outcomes after carotid stenting for high-risk patients and endarterectomy for standard-risk patients. Journal of Vascular Surgery. 2006;43:953-58. [pmid: 16678689].
58 McPhee JT, Hill JS, Ciocca RG, Messina LM, Eslami MH. Carotid endarterectomy was performed with lower stroke and death rates than carotid artery stenting in the United States in 2003 and 2004. Journal of Vascular Surgery. 2007;46:1112-18. [pmid: 18154987].
59 McPhee JT, Schanzer A, Messina LM, Eslami MH. Carotid artery stenting has increased rates of postprocedure stroke, death, and resource utilization than does carotid endarterectomy in the United States, 2005. Journal of Vascular Surgery. 2008;48:1442-50. [pmid: 18829236].
60 Sidawy AN, Zwolak RM, White RA, Siami FS, Schermerhorn ML, Sicard GA, et al. Risk-adjusted 30-day outcomes of carotid stenting and endarterectomy: results from the SVS Vascular Registry. Journal of Vascular Surgery. 2009;49:71-79. [pmid: 19028045].
61 Giacovelli JK, Egorova N, Dayal R, Gelijns A, McKinsey J, Kent KC. Outcomes of carotid stenting compared with endarterectomy are equivalent in asymptomatic patients and inferior in symptomatic patients. Journal of Vascular Surgery. 2010;52:906-13. 913. [pmid: 20620010].
62 Silver FL, Mackey A, Clark WM, et al. Safety of stenting and endarterectomy by symptomatic status in the Carotid Revascularization Endarterectomy Versus Stenting Trial (CREST). Stroke. March. 2011;42(3):675-80. [pmid: 21307169].
63 Howard VJ, Lutsep HL, Mackey A, et al. Influence of sex on outcomes of stenting versus endarterectomy: a subgroup analysis of the Carotid Revascularization Endarterectomy versus Stenting Trial (CREST). Lancet Neurology. June. 2011;10(6):530-7. [pmid: 21550314].
64 Zhang C, Qu S, Li H, et al. Microembolic signals and carotid plaque characteristics in patients with asymptomatic carotid stenosis. Scand Cardiovasc J. 2009;43(5):345-51. [pmid: 19863395].
65 Ogata T, Yasaka M, Wakugawa Y, et al. Long-term results of medical and surgical therapy for Japanese patients with moderate carotid stenosis. J Stroke Cerebrovasc Dis. Jan. 2012;21(1):24-29. [pmid: 20851631].
66 De RP, Parlani G, Verzini F, et al. Long-term prevention of stroke: a modern comparison of current carotid stenting and carotid endarterectomy. Journal of the American College of Cardiology. Feb. 8. 2011;57(6):664-71. [pmid: 21292127].
67 Bangalore S, Bhatt DL, Rother J, et al. Late outcomes after carotid artery stenting versus carotid endarterectomy: insights from a propensity-matched analysis of the Reduction of Atherothrombosis for Continued Health (REACH) Registry. Circulation. Sep. 14. 2010;122(11):1091-100. [pmid: 20805431].
68 Lindstrom D, Jonsson M, Formgren J, et al. Outcome after 7 years of carotid artery stenting and endarterectomy in Sweden - single centre and national results. Eur J Vasc Endovasc Surg. May. 2012;43(5):499-503. [pmid: 22342694].