# Baseline characteristics and results of included studies

Appendix E. Table 1 Baseline characteristics of studies of medical therapy alone

Author, Year Country PMID | Enroll yr | N | f/u (y) | % Male | Age (yr) | Degree of stenosis | Imaging | HTN (%) | Hyper - lipidemia (%) | DM (%) | Smoker * (%) | CHD (%) | Prev CEA (%) | >70 % stenosis (%) | Anti-thrombotic (%) | LLT (%) | Quality
RCT
ACAS, 1995 USA 7723155 | 1987-1993 | 834 | 5.25 | 66 | 67 | 60-99% | DUS | 64 | | 21 | 24 | 69 | 19 | 29 | 100 | Y; nd on coverage | A
Abbott, 2005 Australia 15879327 | 1996-2000 | 202 | 3 | 68 | 74 | 60-99% | DUS | 72 | 67 | 17 | 14 | 52 | 0 | 49 | 93 | 75 | A
ECST, 1995 Europe 7823712 | Before 1992 | 127 | 3.5 | 71 | 64 | 70-99% | DSA | nd | nd | 14.2 | 50 | 33 | 0 | 100 | 100 | nd | B
Halliday, 2004, 2010 (ACST) Multicenter 15135594, 20870099 | 1993-2003 | 1560 | 4.4 | 66 | 68 | 60-99% | DUS | 65 | nd | nd | nd | nd | 24 | nd | 100 | 82 | A
Hobson, 1993 (VA) USA 8418401 | 1983-1987 | 233 | 9 | 100 | 64.7 | 50-99% | DUS DSA | 64 | nd | nd | 91 | 25 | 0 | nd | 84 | nd | A
Inzitari, Anderson, 2000, 2002 USA 10841871, 12154246 | 1988-1997 | 324 | 2.4 | 68 | 66 | 50-99% | DSA | 60 | 32 | 22 | 33 | 36 | ∼50% | 32 | 95 | nd | A
Prospective studies
AbuRahma, 2003 USA 14681599 | 1991-2000(2 RCTs) | 101 | 3.4 | nd | nd | 50-99% | DUS | nd | nd | nd | nd | nd | 100 | 36^##^ | nd | nd | B
AbuRahma, 2003 USA 14530726 | nd | 82 | 5 | 55 | 66 | 60-69% | DUS | 71 | 49 | 38 | 59 | 46 | 0 | 0 | 100 | nd | B
Aichner, 2009 Austria 19473362 | nd | 3164 | 3.2 | 64 | 71 | 70-99% | DUS DSA | 87 | 74.2 | 37.1 | 18.5 | 54.8 | 0 | 100 | 90 | 71 | C
Ballotta, 2007 Italy 17275244 | 1995-2004 | 98 | 2.7 | 62.1 | 71 | 50-69% | DUS DSA | 57.1 | 43.1 | 33 | 67.6 | 44.6 | 100 | 0 | 100 | nd | B
Bock, 1993 Australia 8421333 | 1985-1991 | 74 | 1 | 78 | 68.1 | 50-99% | DUS | 59 | nd | 23 | 35 | 57 | 0 | 13.7^##^ | 27 | nd | B
Bogousslavsky, 1986 Switzerland 3703297 | 1980-1984 | 38 | 4.1 | 55 | 60 | 90-99% | DUS | 52.6 | nd | 21.1 | 73.7 | 79 | 0 | 100 | 100 | 0 | C
CASANOVA, 1991 Germany 1926232 | 1982-1988 | 111 | 6 | 82.5 | 64.1 | 50-90% | DUS DSA | 62 | 52 | 33 | 24 | 42 | 26 | 54 | 100 | nd | C
Dick, 2005 Austria 15890998 | 1997-2002 | 525 | 4 | 62 | 73 (median) | 70-99% | DUS | 75 | 76 | 34 | 19 | 43 | 0 | 100 | 37 | 62 | C
Ellis, 1992 UK 1572457 | 1985-1989 | 164 | 3.2 | nd | nd | 50-99% | DUS | nd | nd | nd | nd | nd | nd | nd | nd | nd | C
Goessens, 2007 The Netherlands 17363718 | 1996 | 221 | 4.5 | 73 | 64.5 | 50-99% | DUS | nd | nd | 21 | 90 | 59 | 0 | nd | 63 | 45 | A
Gronholdt, 2001 Denmark 11435340 | 1994-1996 | 111 | 4 | 53 | 64 | 50-99% | DUS | 38 | nd | 9 | 56 | nd | 0 | 27^##^ | nd | nd | B
Gur, 1996 Israel 8969778 | 1995 | 44 | 3.6 | 50 | 69 | 70-99% | DUS DSA | 66 | 23 | 41 | 25 | nd | nd | 100 | 100 | nd | C
Hennerici, 1987 Germany 3580834 # | 1978-1985 | 235 | 2 | 59 | 61.8 | 50-99% | DUS | 54 | 38 | 23 | | 81 | 0 | 15^##^ | 31 | 0 | C
Johnson, 1985 USA 7823350 | 1981-1984 | 121 | 4 | nd | | 75-99% | nd | nd | nd | nd | nd | nd | 0 | 100 | 0 | nd | C
Johnson, 1995 USA 7823350 | nd | 94 | 2.9 | 62 | | 50-79% | DUS | nd | nd | nd | nd | nd | 0 | nd | nd | nd | C
Langsfeld, 1989 Australia 2651727 # | 1983-1987 | 225 | 7 | 83 | 66.5 | 50-99% | DUS | 51 | nd | nd | 81 | 41 | 100 | 1.3^###^ | nd | nd | C
Levien, 1984 South Africa 6523303 | 1984 | 50 | 3 | nd | nd | nd | DUS | nd | nd | nd | nd | nd | 0 | nd | nd | nd | C
Liapis, 2001 Greece 11739973 | 1988-1997 | 136 | 1.8 | nd | nd | nd | DUS | nd | nd | nd | nd | nd | 0 | 31.6 | nd | nd | C
Longstreth, 1998 USA 9804651 | nd | 184 | 1.5 | nd | 73 | 50-99% | DUS | nd | nd | nd | nd | nd | 0 | 27 | nd | nd | B
Mackey, 1997 Canada 9109874 # | 1988-1994 | 357 | 3.7 | 40 | 65 | 50-99% | DUS | 47 | 50 | 20 | 35 | 39 | 0 | 42^##^ | nd | nd | B
Mansour, 1999 USA 9950980 | 1992-1996 | 344 | 5 | 100 | 70.6 | 50-79% | DUS | 78 | 27 | 36 | 67 | 61 | 0 | nd | 62 | nd | B
Markus, 2010 International 20554250 | nd | 467 | 3.1 | 74 | 71.5 | 70-99% | DUS | 90 | nd | 21 | 61 | 36.9 | nd ^ | 40^##^ | 95.9 | 64 | A
Marquardt, 2010 UK 19926843 | 2002-2009 | 101 | 2.1 | 61 | 71.5 | 50-99% | DUS | 68 | nd | 16 | 75 | 14 | nd | 32 | 96 | 88 | A
Mayo, 1992 USA 1434877 | ∼1990 | 90 | 2 | 57.3 | nd | 50-99% | DUS DSA | 72 | 62 | 18 | 73.5 | 40 | 0 | nd | 100 | nd | B
Nicolaides, Kakkos, 2005 UK 16130207, 16158030 | nd | 805 | 3 | 61 | 70 | 50-99% | DUS | 63 | 60 | 21 | 71 | 34 | 0 | 56 | 84 | 25 | B
Norris, 1991 Canada 1962321 | nd | 393 | 2 | 54 | 65.6 | 50-100% | DUS | 50 | 30 | 15 | 77 | 37 | nd | 45^###^ | 54 | nd | C
Sabeti, 2007 Austria 17885257 # | 2002-2003 | 613 | 3.1 | 63 | 71.8 | 50-99% | DUS | 72 | 73 | 24.5 | 27 | 43 | nd | nd | 56 | 59 | B
Satiani, 1990 USA 2364044 # | nd | 57 | 3.2 | 44 | 67.6 | 50-99% | DUS DSA | 49 | nd | 24 | 56 | 54 | 0 | 27^##^ | nd | nd | C
Satiani, 1993 USA 8356526 # | nd | 127 | 3.4 | 50 | 67.5 | 50-99% | DUS | nd | nd | nd | nd | nd | 100 | 0.4^##^ | nd | nd | C
Siebler, 1995 Germany 7482670 | nd | 64 | 3.6 | 75 | 65.5 | 70-90% | DUS | 60.9 | | 17.2 | 57.8 | 46.9 | 0 | 100 | 78.2 | | C
Silvestrini, 2000 Italy 10791504 | 1996-1998 | 94 | 2 | 79 | 71 | 70-90% | DUS | 70 | 32 | 30 | 37 | nd | 0 | 100 | 100 | 32 | B
Spence, 2005, 2010 Canada 20008646, 16224084 | 2000-2007 | 468 | 1.4 | 57.8 | 69.8 | 60-99% | DUS | 75.4 | 50.8 | 18.6 | 18.1 | 33.2 | nd | nd | 81 | 13.6 | A
Takahashi, 2006 Japan 16788300 | 1994-2001 | 2924 | 2.3 | 65 | 55 | 50-99% | DUS | 12 | 5 | 3 | nd | nd | nd | nd | 0 | 5 | C
Takaya, 2006 USA 16469957 | nd | 154 | 2 | 82 | 71.1 | 50-79% | DUS | 75 | 79 | 25 | 87 | 44 | nd | nd | | 64 | B
Zhang, 2009 China 19863395 | nd | 62 | 1 | nd | 65.5 | 50-99% | DUS | nd | nd | nd | nd | nd | nd | 30.6 | nd | nd | B

* Current or past smoker;

# Baseline values are for the overall population sample from which patients with >50% stenosis were selected;

## ≥ 80% stenosis;

### ≥ 75% stenosis; f/u = followup; HTN = Hypertension; DM = Diabetes mellitus; CHD = Coronary heart disease; PVD = Peripheral vascular disease; CEA = Carotid endarterectomy; LLT = Lipid lowring therapy, which includes statins and other drugs;

^ In Markus 2010, the population included patients who had undergone CEA for the contralateral artery, but their numbers or proportion was not known.

Appendix E. Table 2 Baseline characteristics of RCTs of CEA versus medical therapy

Author, Year Country PMID | Group | N enrolled (analyzed) | Male, % | Age, yr | % age >80yr | HTN % | Afib/AFlutter % | Hyperlipidemia (%) | DM % | Smokers % (define) | CAD % | PVD % | Previous TIA % | Previous CEA % | % ≥70% stenosis | Contralateral occlusion % | previous CAS %
VA, 1993 US 8418401 | Medical | 233 (233) | 100 | 64.7 (6.7) | nd | 64 | 14 | nd | 27 | 49 (daily) 42 (former) | 25 | 59 | 26 | 0 | nd | 33 | 0
VA, 1993 US 8418401 | CEA+medical | 211 (211)^1^ | 100 | 64.1 (6.8) | nd | 63 | 17 | nd | 30 | 52 (daily) 43 (former) | 30 | 61 | 26 | 0 | nd | 32 | 0
ACAS, 1995 USA 7723155 | CEA | 825 | 66 | 67 | 0 | 64 | nd | nd | 25 | 28 (current) | 69 | nd | 22 | 20 | 58 (29)^2^ | 10 | 0
ACAS, 1995 USA 7723155 | Medical | 834 | 66 | 67 | 0 | 64 | nd | nd | 21 | 24 (current) | 69 | nd | 27 | 19 | 58 (29) | 9 | 0
ACST, 2004, 2010, Multicenter 15135594 20870099 | Both (Immediate CEA vs Deferred CEA) | 3120 (3120) | 66 | 68 (40-91) | 21 | 65 | 0 | nd | 20 | nd | nd | nd | nd^3^ | 24 | nd | 9 | NA

1 8 patients declined surgery after randomization, but were treated as ITT

2 29% had above 80% stenosis

3 12% had ipsilateral symptoms

Appendix E. Table 3 Baseline characteristics of prospective nonrandomized comparative studies of CEA vs medical therapy

Author, Year Country Design | Group | N enrolled (analyzed) | Male, % | Age yr | % age >80yr | HTN % | AFib/Aflutter % | Hyperlipid Emia % | DM % | Smokers % (define) | CAD % | PVD % | Previous TIA % | Previous CEA % | % ≥70% stenosis | Contralateral occlusion % | Previous CAS %
CASANOVA, 1991 Germany Prospective^4^ | CEA | 122 | 83.2 | 64.4 | nd | 59 | nd | 48 | 26 | 29 (nd) | 44 | 56 | 0 | 27 | 50 | 0 | 0
CASANOVA, 1991 Germany Prospective^4^ | medical | 111 | 82.5 | 64.1 | nd | 62 | nd | 52 | 33 | 24 (nd) | 42 | 50 | 0 | 26 | 54 | 0 | 0
Mayo, 1992 USA 1434877 | CEA (RCT) | 36 | 55.6 | nd | 0 | 64 | 0 | 44.4 | 19.4 | 66.7 (ever) | 41.6 | 22.2 | 0 | 0 | nd | 0 | 0
Mayo, 1992 USA 1434877 | Medical (RCT) | 35 | 60 | nd | 0 | 63 | 0 | 65.7 | 14.3 | 74.3 (ever) | 40.0 | 22.9 | 0 | 0 | nd | 0 | 0
Mayo, 1992 USA 1434877 | CEA (NRCS) | 32 | 81.2 | nd | 0 | 84.4 | 0 | 59.4 | 18.8 | 81.3 | 43.7 | 46.9 | 0 | 0 | nd | 0 | 0
Mayo, 1992 USA 1434877 | Medical (NRCS) | 55 | 54.6 | nd | 0 | 80 | 0 | 58.2 | 21.8 | 72.7 | 40 | 36.4 | 0 | 0 | nd | 0 | 0

4 Proportion applies to a larger sample

Appendix E. Table 4 Baseline characteristics of retrospective comparative studies of CEA versus medical therapy

Author, Year Country PMID | Group | N enrolled (analyzed) | Male % | Age yr | % age >80 yr | HTN % | AFib % | Hyperlipid Emia % | DM % | Smokers % (define) | CAD % | PVD % | Previous TIA % | Previous CEA % | % ≥70% stenosis | Contralateral occlusion % | Previous CAS %
Hertzer, 1986 3527089 | CEA | 95 | 66 | 64 | nd | 71 | nd | nd | 20 | nd | nd | nd | 0 | nd | nd | nd | NA
Hertzer, 1986 3527089 | MEDICAL | 195 | 64 | 67 | nd | 62 | nd | nd | 19 | nd | nd | nd | 0 | nd | nd | nd | NA
Libman, 1994 USA 8059320 | CEA | 107(101) | 63 | 66.7 | nd | 69 | nd | 20 | 15 | 75 (ever smoked) | MI = 23, angina = 20 | nd | nd | 36^5^ | 76%^6^ | nd | NA
Libman, 1994 USA 8059320 | Med | 108 (106) | 51 | 69.3 | nd | 52 | nd | 43 | 23 | 56 (ever smoked) | MI = 11, angina = 27 | nd | nd | 12^7^ | 68%^8^ | nd | NA
Poulias, 1994 Greece 7820518 | Both | 134^9^ | 86 | 58 (28 – 42) | 0 | 23.4^10^ | nd | nd | nd | nd | nd | nd | nd | nd | nd | 141^11^ | NA
Bosiers, 2005 15996363 Belgium | CEA | 20 | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | 100 | nd | Nd
Bosiers, 2005 15996363 Belgium | medical | 16 | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | 100 | nd | Nd
Caracci, 1989 USA | CEA | 79 | 49 | 65 | nd | 49 | nd | nd | nd | 57 | 32 | nd | 0 | 0 | nd | nd | NA
Caracci, 1989 USA | Medical | 62 | 65 | 60 | nd | 65 | nd | nd | nd | 65 | 32 | nd | 0 | 0 | nd | nd | NA

5 For the contralateral artery

6 >80% stenosis

7 For the contralateral artery

8 >80% stenosis

9 100 operated patients and 34 unoperated patients in the asymptomatic group

10 For the whole cohort of patients with and without symptoms (n=700)

11 For the whole cohort of patients with and without symptoms (n=700)

Appendix E. Table 5 Results of RCTs of CEA versus medical therapy

Author, Year Country PMID | Total (n) | Intervention (n) | Control (n) | Age (yr) | Male % | CAD % | DM % | % ≥70% stenosis | | Followup (yr) | Outcome | Metric* | Result | 95 % CI | P btw | Study quality
Ipsilateral stroke
VA, 1993 US 8418401 | 444 | 211 | 233 | 63 | 100 | 28 | 29 | nd | | 3.9 | Any stroke or death (30 d); ipsilateral stroke >30 d | RR | 0.75 | 0.42, 1.35 | NS | A
ACAS, 1995 USA, Canada 7723155 | 1659 | 825 | 834 | 67 | 66 | 69 | 23 | 58 | | 2.7 | Any stroke or death (30 d); ipsilateral stroke >30 d | RR | 0.64 | 0.42, 0.98 | 0.041 | A
ACST, 2004, Multicenter 15135594 | 3120 | 1560 | 1560 | 68 | 66 | nd | 20 | nd | | 5 | Any stroke or death (30 d); ipsilateral stroke >30 d | RR | 0.73 | 0.51, 1.03 | NS | A
ACST, 2010, Multicenter 20870099 | 3120 | 1560 | 1560 | 68 | 66 | nd | 20 | nd | | 10 | Any stroke or death (30 d); ipsilateral stroke >30 d | RR | 0.76 | 0.57, 1.01 | NS | A
Any stroke
VA, 1993 US 8418401 | 444 | 211 | 233 | 63 | 100 | 28 | 29 | nd | | 3.9 | Any stroke or death (30 d); any stroke >30 d | RR | 0.92 | 0.56, 1.51 | NS | A
ACAS, 1995 USA, Canada 7723155 | 1659 | 825 | 834 | 67 | 66 | 69 | 23 | 58 | | 2.7 | Any stroke or death (30 d); any stroke >30 d | RR | 0.71 | 0.51, 0.97 | 0.03 | A
ACST, 2004, Multicenter 15135594 | 3120 | 1560 | 1560 | 68 | 66 | nd | 20 | nd | | 5 | Any stroke or death (30 d); any stroke >30 d | RR | 0.63 | 0.48, 0.82 | <0.05 | A
ACST, 2010, Multicenter 20870099 | 3120 | 1560 | 1560 | 68 | 66 | nd | 20 | nd | | 10 | Any stroke or death (30 d); any stroke >30 d | RR | 0.61 | 0.49, 0.76 | <0.05 | A
Any stroke or death
VA, 1993 US 8418401 | 444 | 211 | 233 | 63 | 100 | 28 | 29 | nd | | 3.9 | Any stroke or death | RR | 0.93 | 0.75, 1.16 | NS | A
ACAS, 1995 USA, Canada 7723155 | 1659 | 825 | 834 | 67 | 66 | 69 | 23 | 58 | | 2.7 | any stroke or death | RR | 0.81 | 0.65, 1.00 | 0.084 | A
ACST, 2004, Multicenter 15135594 | 3120 | 1560 | 1560 | 68 | 66 | nd | 20 | nd | | 5 | Any stroke or death | RR | 0.95 | 0.83, 1.09 | NS | A
ACST, 2010, Multicenter 20870099 | 3120 | 1560 | 1560 | 68 | 66 | nd | 20 | nd | | 10 | Any stroke or death | RR | 0.97 | 0.90, 1.05 | NS | A
Any death
VA, 1993 US 8418401 | 444 | 211 | 233 | 63 | 100 | 28 | 29 | nd | | 3.9 | Any death | RR | 1.03 | 0.80, 1.34 | NS | A
ACAS, 1995 USA, Canada 7723155 | 1659 | 825 | 834 | 67 | 66 | 69 | 23 | 58 | | 2.7 | Any death | RR | 0.92 | 0.70, 1.22 | NS | A
ACST, 2010, Multicenter 20870099 | 3120 | 1560 | 1560 | 68 | 66 | nd | 20 | nd | | 10 | Any death | RR | 1.07 | 0.98, 1.17 | NS | A
Events within 30 d randomization
VA, 1993 US 8418401 | 444 | 211 | 233 | 63 | 100 | 28 | 29 | nd | | 30 d | Stroke or death (30 d) | RR | 3.68 | 1.03, 13.2 | 0.045 | A
ACAS, 1995 USA, Canada 7723155 | 1659 | 825 | 834 | 67 | 66 | 69 | 23 | 58 | | 30 d | any stroke, death: <30 days | RR | 6.40 | 1.90, 21.55 | 0.003 | A
Halliday, 2004, 2010, Multicenter 15135594 20870099 | 3120 | 1560 | 1560 | 68 | 66 | nd | 20 | nd | | 30 d | Periprocedural stroke death | RR | 5.03 | 1.10, 22.98 | 0.04 | A

Appendix E. Table 6 Results characteristics of prospective nonrandomized studies of CEA versus medical therapy

Author, Year Country PMID | Total (n) | Intervention (n) | Control (n) | Age (yr) | Male % | CAD % | DM % | % ≥70% stenosis | | Followup (yr) | Outcome | Metric* | Result | 95 % CI | P btw | Study quality
CASANOVA, 1991 Germany 1926232 | 233 | 122 | 111 | 64.1 | 82.5 | 43 | 30 | 52 | | 3 | Any stroke and death due to surgery or stroke | RR | 0.78 | 0.38, 1.61 | 0.503 | B
Mayo, 1992 USA 1434877 (RCT) | 71 | 36 | 35 | nd | 57 | 41 | 17 | nd | | 1.96 | Any stroke, TIA, death | OR | 0.97 | 0.26, 3.58 | 0.966 | B
Mayo, 1992 USA 1434877 (RCT) | 71 | 36 | 35 | nd | 57 | 41 | 17 | nd | | 1.96 | Any stroke | OR | 5.83 | 0.30, 112. | 0.243 | B
Mayo, 1992 USA 1434877 (NRCS) | 87 | 32 | 55 | nd | 68.3 | 41.5 | 21 | nd | | 1.96 | Any stroke, TIA, death | OR | 3.44 | 0.92, 12.8 | 0.066 | B
Mayo, 1992 USA 1434877 (NRCS) | 87 | 32 | 55 | nd | 68.3 | 41.5 | 21 | nd | | 1.96 | Any stroke | OR | 6.88 | 0.80, 58.8 | 0.078 | B

Appendix E. Table 7 Results of retrospective nonrandomized studies of CEA versus medical therapy

Author, Year Country PMID | Total (n) | Intervention (n) | Control (n) | Age (yr) | Male % | CAD (% | DM (%) | % ≥70% stenosis | | Followup (yr) | Outcome | Metric* | Result | 95 % CI | P btw | Study quality
Libman, 1994 USA 8059320 | 215 | 107 | 108 | 68y | 57 % | MI:17%, Angina: 24% | 19 % | 72%^12^ | | 0.083 | Periprocedural ipsilateral Stroke | OR | 11.1 | 0.62, 198.33 | 0.102 | C
Libman, 1994 USA 8059320 | 215 | 107 | 108 | 68y | 57 % | MI:17%, Angina: 24% | 19 % | 72%^12^ | | 0.083 | Ipsilateral stroke | OR | 1.47 | 0.48, 4.48 | 0.499 | C
Libman, 1994 USA 8059320 | 215 | 107 | 108 | 68y | 57 % | MI:17%, Angina: 24% | 19 % | 72%^12^ | | 0.083 | Any stroke | OR | 0.80 | 0.41, 1.57 | 0.519 | C
Libman, 1994 USA 8059320 | 215 | 107 | 108 | 68y | 57 % | MI:17%, Angina: 24% | 19 % | 72%^12^ | | 0.083 | Stroke - free survival | OR | 1.17 | 0.98, 1.39 | 0.076 | C
Poulias 1994 Greece 7820518 | 134^13^ | 100 | 34 | 58 (28 – 42) | 86 | ND | ND | ND | | 5.2 (0.3 – 10) | Neurological deficit | OR | 0.02 | 0, 0.39 | 0.01 | C
Poulias 1994 Greece 7820518 | 134^13^ | 100 | 34 | 58 (28 – 42) | 86 | ND | ND | ND | | 5.2 (0.3 – 10) | Death | OR | 0.01 | 0, 0.20 | 0.002 | C
Bosiers, 2005 15996363 Belgium | NRCS, retro | 20 | 16 | nd | nd | nd | nd | nd | | 30 days | Any stroke or death | OR | Non - estimable | | | C
Ogata 2012 20851631 Japan | NRCS, retro | 51 | 42 | 70 | nd | nd | nd | nd | | nd | Any stroke | RR | 0.69 | 0.23, 2.09 | | C

12 >80% stenosis

13 100 operated patients and 34 unoperated patients in the asymptomatic group

Appendix E. Table 8 Baseline Characteristics of CAS versus medical therapy

Author, Year Country PMID | Group | N enrolled (analyzed) | Male % | Age yr | % age >80 yr | HTN % | AFib/AFlutter % | Hyperlipid emia % | DM % | Smokers, % (define) | CAD % | PVD % | Previous TIA % | Previous CEA % | % ≥70% stenosis | Contralateral occlusion % | Previous CAS %
Sherif, 2005 Austria 15823061 | CAS | 499 (421) | 68 | 72 | nd | 78 | nd | 77 | 37 | 17 (current) | 46 | 49 | 0 | 0 | 100 | 15 | 0
Sherif, 2005 Austria 15823061 | medical | 616 (525) | 68 | 73 | nd | 75 | nd | 76 | 34 | 19 (current) | 43 | 41 | 0 | 0 | 100 | 6 | 0
Bosiers, 2005 15996363 Belgium | CAS | 59 | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | 100 | nd | nd
Bosiers, 2005 15996363 Belgium | medical | 16 | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | 100 | nd | nd

Appendix E. Table 9 Results of CAS versus Medical therapy

Study PMID | Design | Total (n) | Intervention (n) | Control (n) | Age (yr) | Male % | CAD % | DM % | % ≥70% stenosis | Followup (yr) | Outcome | Metric^*^ | Result | 95 % CI | P btw | Study quality
Sherif, 2005 Austria 15823061 | NRCS, retro | 946 | 421 | 525 | 73 | 64 | 44 | 35 | 100 | 5 | Any stroke or death | HR^*^ | 0.66 | 0.49,0.91 | 0.012 | B
Sherif, 2005 Austria 15823061 | NRCS, retro | 946 | 421 | 525 | 73 | 64 | 44 | 35 | 100 | 5 | Any stroke | HR^*^ | 0.47 | 0.24,0.90 | 0.023 | B
Sherif, 2005 Austria 15823061 | NRCS, retro | 946 | 421 | 525 | 73 | 64 | 44 | 35 | 100 | 5 | Death | HR^*^ | 0.67 | 0.46,0.97 | 0.035 | B
Bosiers, 2005 Belgium 15996363 | NRCS, retro | 75 | 59 | 16 | nd | nd | nd | nd | 100 | 30 days | Any stroke or death | | Not estimable | | | C

CI = confidence interval, HR = hazard ratio, NRCS = non randomized comparative study, nd = no data, RR = relative risk.

* Adjusted for age (in quartiles), sex, body mass index, arterial hypertension, diabetes mellitus, hyperlipidemia, smoking, baseline degree of stenosis, (70% to 79%, 80% to 89%, 90% to 99%), history of MI, congestive heart failure (NYHA), peripheral artery disease (Fontaine), presence of a malignancy, surgical risk assessed by the American Society of Anesthesiologists score (I to IV), use of statins and clopidogrel, and the propensity for carotid stenting.

NRCS with propensity score matching, all pts >70 percent stenosis, available subgroup results by categories of stenosis in KM curves, single CAS interventionist, robust methods of outcome ascertainment, diagnostic modality validated.

Appendix E. Table 10 Baseline characteristics of patients in the CAS versus CEA

Author, Year Country PMID | Study Design | Group | N | Male % | Age yr | % age >80y | HTN % | AFib/Aflutter % | % hyperlipidemia | DM, % | Smokers, % (define) | % CAD | % PVD | % previous Stroke/TIA | % previous CEA | % ≥70% stenosis | % contralateral occlusion | % previous CAS
CREST 2010; 2011 USA 20505173; 21307169 21550314 | RCT | CAS | 594 | 63.8 | 69 | nd | 88.2 | nd | 89.7 | 32.6 | 26.1 (current ) | 48.6 | nd | nd | nd | 92.8 | 2.3 | nd
CREST 2010; 2011 USA 20505173; 21307169 21550314 | RCT | CEA | 587 | 67.5 | 69.6 | nd | 87.9 | nd | 91.1 | 33.7 | 22.2 (current ) | 50.9 | nd | nd | nd | 91.8 | 2.7 | nd
Yadav 2004, Gurm 2008, USA 15470212; 18403765 | RCT | CAS | 117 | 66.9^*^ | 72.5^*^ | 19.3^*^ | 85.5^*^ | Nd | 78.5^*^ | 25.3^*^ | 16.9^*^ (current) | 85.8^*^ | Nd | 2.8 | 22.6^*^ | 100 | 23.6^*^ | Nd
Yadav 2004, Gurm 2008, USA 15470212; 18403765 | RCT | CEA | 121 | 67.1^*^ | 72.6^*^ | 20.5^*^ | 85.1^*^ | nd | 76.9^*^ | 27.5^*^ | 16.4^*^ (current) | 75.5^*^ | nd | 3.9 | 22.2^*^ | 100 | 25.3^*^ | Nd
Brooks, 2004 USA 14744277 | RCT | CAS | 43 | Nd | 66.6 | Nd | 82 | Nd | 21 | 16 | 93 | 81.4 | Nd | Nd | Nd | 100 | Nd | Nd
Brooks, 2004 USA 14744277 | RCT | CEA | 42 | nd | 69.9 | nd | 98 | nd | 21 | 12 | 88 | 47.6 | nd | nd | nd | 100 | nd | Nd
CaRESS, 2005 2009, USA, 16102616;19702339 | NRCS, prosp | CAS | 99 | 60^*^ | 71.2^*^ | 19^*^ | 81^*^ | Nd | 64^*^ | 29^*^ | 77^*^ (ever) | 66^*^ | 45^*^ | nd | nd | 94^*^ | nd | 6^*^
CaRESS, 2005 2009, USA, 16102616;19702339 | NRCS, prosp | CEA | 170 | 63^*^ | 71.4^*^ | 19^*^ | 81^*^ | Nd | 70^*^ | 24^*^ | 77^*^ (ever) | 61^*^ | 41^*^ | Nd | Nd | 89^*^ | Nd | 0
De Rango, 2011, Italy 21292127^§^ | NRCS, prosp | CAS | 816 | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd
De Rango, 2011, Italy 21292127^§^ | NRCS, prosp | CEA | 702 | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd
Marine, 2006 1434877 USA Bosiers, 2005 15996363 Belgium | NRCS, retro NRCS, retro | CAS | 93 | 63.4 | 69.8 | 20 | 77.2 | nd | 66.9 | 30.3 | 54.5 (ever) | 57.9 | 37.9 | nd | nd | 100 | nd | nd
Marine, 2006 1434877 USA Bosiers, 2005 15996363 Belgium | NRCS, retro NRCS, retro | CEA | 145 | 61.4 | 69.6 | 18.3 | 91.4 | nd | 75.3 | 37.6 | 58.1 (ever) | 74.2 | 33.3 | nd | nd | 100 | nd | nd
Marine, 2006 1434877 USA Bosiers, 2005 15996363 Belgium | NRCS, retro NRCS, retro | CAS | 59 | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | 100 | nd | Nd
Marine, 2006 1434877 USA Bosiers, 2005 15996363 Belgium | NRCS, retro NRCS, retro | CEA | 20 | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | 100 | nd | Nd
McPhee, 2008 USA 18829236 | NRCS, retro^†^ | CAS | 11302 | 62.9 | 71.6 | Nd | 65.7 | nd | nd | 26.5 | nd | 11.8 | nd | 0 | nd | nd | nd | nd
McPhee, 2008 USA 18829236 | NRCS, retro^†^ | CEA | 111684 | 57.2 | 71.1 | nd | 71.9 | nd | nd | 26.6 | nd | 11.0 | nd | 0 | nd | nd | nd | nd
McPhee, 2007 USA 18154987 | NRCS, retro^†^ | CAS | 12278 | 59.3 | 70.5 | nd | 66.7 | nd | nd | 25.8 | nd | 11.7 | nd | 0 | nd | nd | nd | nd
McPhee, 2007 USA 18154987 | NRCS, retro^†^ | CEA | 226111 | 56.9 | 71.2 | nd | 70.8 | nd | nd | 25.4 | nd | 11.8 | nd | 0 | nd | nd | nd | nd
Sidawy, 2009 USA 19028045 | NRCS, retro^†^ | CAS | 1404 (805) | 59.5^*^ | 70.8^*^ | nd | 81.6^*^ | 13.8^*^ | nd | 33.0^*^ | 59.3 | 61.4^*^ | 38.3^*^ | nd | 24.3^*^ | nd | nd | nd
Sidawy, 2009 USA 19028045 | NRCS, retro^†^ | CEA | 1877 (862) | 59.7^*^ | 71.2^*^ | nd | 71.8^*^ | 11.1^*^ | nd | 26.1^*^ | 55.6^*^ | 45.7^*^ | 46.1^*^ | nd | 1.1^*^ | nd | nd | nd
Giacovelli, 2010 USA 20620010 | NRCS, retro^†^ | CAS | 4354 | 59.9 | 71.4 | nd | 73.8 | 13.7 | 49.4 | 28.5 | nd | 47.3 | nd | nd | nd | nd | nd | nd
Giacovelli, 2010 USA 20620010 | NRCS, retro^†^ | CEA | 4354 | 60.2 | 72.0 | nd | 74.3 | 14.3 | 50.5 | 29.8 | nd | 49.2 | nd | nd | nd | nd | nd | Nd
Bangalore, 2010, International, 20805431 | Registry, prosp | CAS | 836 | 68.1 | 70 | nd | 86.0 | 13.6 | 78.3 | 41 | 64.0 | 49.5 | nd | 19.5 | nd | nd | nd | nd
Bangalore, 2010, International, 20805431 | Registry, prosp | CEA | 836 | 66.6 | 69 | nd | 86.8 | 14.1 | 78.3 | 44 | 65.4 | 47.6 | nd | 20.0 | nd | nd | nd | nd
Lindstrom, 2012, Sweden, 22342694 | Registry | CAS | 101 | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd
Lindstrom, 2012, Sweden, 22342694 | Registry | CEA | 1315 | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd | nd

RCT, randomized controlled trial; NRCS, nonrandomized comparative study; retro, retrospective; prosp, prospective; CEA, carotid endarterectomy; CAS, carotid artery stenting; CAD, coronary artery disease; HTN, hypertension; DM, diabetes mellitus; AFib/Aflutter, atrial fibrillation/ atrial flutter; PVD, peripheral vascular disease; TIA, transient ischemic attack.; nd, no data

* Proportion applies to a larger sample of patients

† Administrative dataset

§ Baseline data not available for patients with asymptomatic carotid stenosis

Appendix E. Table 11 Comparison of CAS versus CEA for the outcome of cerebrovascular events

Author, Year Country PMID | Design | Total (n) | CAS (n) | CEA (n) | Age (y) | male (%) | CAD (%) | DM (%) | % ≥ 70% stenosis | Followup | Outcome | Metric | Result | 95 % CI | P btw | Study quality
CREST, 2010, 2011 USA 20505173, 21307169, 21550314 | RCT | 1181 | 594 | 587 | 69.3 | 65.6 | 49.7 | 33.1 | 92.3 | 4y | Any periprocedural stroke or postprocedural ipsilateral stroke | HR^*^ | 1.86 | 0.95, 3.66 | 0.07 | A
Yadav 2004, Gurm 2008, USA 15470212; 18403765 | RCT | 237 | 117 | 120 | 72.5 | 67 | 80.0 | 26.0 | 100 | 1y | Any periprocedural stroke or ipsilateral stroke | RR^†^ | 0.77 | 0.27 -2.14 | 0.617 | B
Yadav 2004, Gurm 2008, USA 15470212; 18403765 | RCT | 237 | 117 | 120 | 72.5 | 67 | 80.0 | 26.0 | 100 | 3y | Any stroke | RR^†^ | 1.12 | 0.51 -2.43 | 0.777 | B
Brooks, 2004 USA 14744277 | RCT | 85 | 43 | 42 | 68.2 | nd | 64.5 | 14 | 100 | 4y | Any stroke/TIA | RR | Non-estimable^‡^ | | | B
CaRESS, 2005 2009, USA, 16102616;19702339 | NRCS, prosp | 269 | 99 | 170 | 71.3 | 62 | 63 | 26 | 91 | 4y | Any stroke | RR^†^ | 1.34 | 0.51 -3.47 | 0.553 | B
Bangalore, 2010, International, 20805431 | Registry, prosp | 1672 | 836 | 836 | 70 | 67 | 49 | 43 | 100 | 1.5y | Any stroke | HR | 1.41 | 0.79-2.51 | 0.25 | C
Bangalore, 2010, International, 20805431 | Registry, prosp | 1672 | 836 | 836 | 70 | 67 | 49 | 43 | 100 | 1.5y | Any Stroke/TIA | HR | 1.10 | 0.71-1.72 | 0.67 | C

RCT, randomized controlled trial; NRCS, nonrandomized comparative study; retro, retrospective; prosp, prospective; CEA, carotid endarterectomy; CAS, carotid artery stenting; CAD, coronary artery disease; DM, diabetes mellitus; TIA, transient ischemic attack; nd, no data; HR, hazard ratio; RR, relative risk

* Adjusted for age and sex

† Calculated from raw data

‡ RR cannot be estimated because no events occurred in any of the treatment arms

Appendix E. Table 12 Comparison of CAS versus CEA for the outcome of mortality

Author, Year Country PMID | Study Design | Total (n) | CAS (n) | CEA (n) | Age (y) | male (%) | CAD (%) | DM(%) | % ≥ 70% stenosis | Followup (y) | Outcome | Metric | Result | 95 % CI | P btw | Study quality
Yadav 2004, Gurm 2008, USA 15470212; 18403765 | RCT | 237 | 117 | 120 | 72.5 | 67 | 80.0 | 26.0 | 100 | 1y | Death | RR | 0.47 | 0.18 -1.20 | 0.116 | B
CaRESS, 2005 2009, USA, 16102616;19702339 | NRCS, prosp | 269 | 99 | 170 | 71.3 | 62 | 63 | 26 | 91 | 4y | Death | RR^*^ | 1.36 | 0.78 -2.35 | 0.273 | B
Bangalore, 2010, International, 20805431 | Registry, prosp | 1672 | 836 | 836 | 70 | 67 | 49 | 43 | 100 | 1.5y | Death | HR | 0.73 | 0.49 – 1.09 | 0.13 | C

RCT, randomized controlled trial; NRCS, nonrandomized comparative study; retro, retrospective; prosp, prospective; CEA, carotid endarterectomy; CAS, carotid artery stenting; CAD, coronary artery disease; DM, diabetes mellitus; TIA, transient ischemic attack; nd, no data; HR, hazard ratio; RR, relative risk

* Calculated from raw data

Appendix E. Table 13 Comparison of CAS versus CEA for the composite outcomes

Author, Year Country PMID | Design | Total (n) | CAS (n) | CEA (n) | Age (y) | male (%) | CAD (%) | DM (%) | % ≥70% stenosis | Followup | Outcome | Metric^*^ | Result | 95 % CI | P btw | Study quality
CREST, 2010 USA 20505173 | RCT | 1181 | 594 | 587 | 69.3 | 65.6 | 49.7 | 33.1 | 92.3 | 4y | Any periprocedural stroke, MI, or death or postprocedural ipsilateral stroke | HR^*^ | 1.17 | 0.69 - 1.98 | 0.56 | A
CREST, 2010 USA 20505173 | RCT | 1181 | 594 | 587 | 69.3 | 65.6 | 49.7 | 33.1 | 92.3 | 4y | Any periprocedural stroke or death or postprocedural ipsilateral stroke | HR^*^ | 1.86 | 0.95 - 3.66 | 0.07 | A
Yadav 2004, Gurm 2008, USA 15470212; 18403765 | RCT | 237 | 117 | 120 | 72.5 | 67 | 80.0 | 26.0 | 100 | 3y | Any periprocedural stroke, MI, or death or postprocedural ipsilateral stroke | RR^†^ | 0.73 | 0.46 - 1.14 | 0.171 | B
Yadav 2004, Gurm 2008, USA 15470212; 18403765 | RCT | 237 | 117 | 120 | 72.5 | 67 | 80.0 | 26.0 | 100 | 1y | Any periprocedural stroke or death or postprocedural ipsilateral stroke | RR^‡^ | 0.54 | 0.28-1.02 | 0.059 | B
De Rango, 2011, Italy 21292127 | NRCS, prosp | 1518 | 816 | 702 | nd | nd | nd | nd | nd | 2.8y | Any periprocedural stroke or death or postprocedural ipsilateral stroke | RR^†^ | 0.83 | 0.49-1.39 | 0.48 | C
CaRESS, 2005 2009, USA, 16102616;19702339 | NRCS, prosp | 269 | 99 | 170 | 71.3 | 62 | 63 | 26 | 91 | 4y | Any stroke or death | RR^†^ | 1.26 | 0.77 - 2.05 | 0.358 | B
CaRESS, 2005 2009, USA, 16102616;19702339 | NRCS, prosp | 269 | 99 | 170 | 71.3 | 62 | 63 | 26 | 91 | 4y | Any stroke or death or MI | RR^†^ | 1.18 | 0.72 - 1.91 | 0.501 | B
Bangalore, 2010, International, 20805431 | Registry, prosp | 1672 | 836 | 836 | 70 | 67 | 49 | 43 | 100 | 1.5y | Any stroke or death | HR | 0.89 | 0.63 – 1.27 | 0.53 | C
Bangalore, 2010, International, 20805431 | Registry, prosp | 1672 | 836 | 836 | 70 | 67 | 49 | 43 | 100 | 1.5y | Any stroke or death or MI | HR | 0.79 | 0.58 – 1.08 | 0.14 | C

RCT, randomized controlled trial; NRCS, nonrandomized comparative study; retro, retrospective; prosp, prospective; CEA, carotid endarterectomy; CAS, carotid artery stenting; CAD, coronary artery disease; DM, diabetes mellitus; TIA, transient ischemic attack; nd, no data; HR, hazard ratio; RR, relative risk

* Adjusted for age and sex

† Calculated from raw data

‡ Calculated from raw data as provided in the FDA website

Appendix E. Table 14 Comparison of CAS versus CEA for the high-surgical risk population

Author, Year Country PMID | Subgroup | Design | Total (n) | CAS (n) | CEA (n) | Followup | Outcome | Metric^*^ | Result | 95 % CI | P btw | Study quality
Yadav 2004, Gurm 2008, USA 15470212; 18403765 | High surgical risk | RCT | 237 | 117 | 120 | 3y | Any periprocedural stroke, MI, or death or postprocedural ipsilateral stroke | RR^*^ | 0.73 | 0.46 - 1.14 | 0.171 | A
Yadav 2004, Gurm 2008, USA 15470212; 18403765 | High surgical risk | RCT | 237 | 117 | 120 | 3y | Any stroke | RR^*^ | 1.12 | 0.51, 2.43 | 0.777 | A

RCT, randomized controlled trial; NRCS, nonrandomized comparative study; retro, retrospective; prosp, prospective; CEA, carotid endarterectomy; CAS, carotid artery stenting; CAD, coronary artery disease; DM, diabetes mellitus; TIA, transient ischemic attack; nd, no data; HR, hazard ratio; RR, relative risk

* Calculated from raw events

Appendix E. Table 15 Comparison of CAS versus CEA for the patients with anatomically advanced disease (>80% stenosis)

Author, Year Country PMID | Subgroup | Design | Total (n) | CAS (n) | CEA (n) | Followup | Outcome | Metric^*^ | Result | 95 % CI | P btw | Study quality
Yadav 2004, Gurm 2008, USA 15470212; 18403765 | >80% | RCT | 237 | 117 | 120 | 3y | Any periprocedural stroke, MI, or death or postprocedural ipsilateral stroke | RR^*^ | 0.73 | 0.46, 1.14 | 0.171 | A
Yadav 2004, Gurm 2008, USA 15470212; 18403765 | >80% | RCT | 237 | 117 | 120 | 30 days | Any stroke, MI, or death | RR^*^ | 0.51 | 0.19, 1.32 | 0.167 | A
Yadav 2004, Gurm 2008, USA 15470212; 18403765 | >80% | RCT | 237 | 117 | 120 | 3y | Any stroke | RR^*^ | 1.12 | 0.51, 2.43 | 0.777 | A
Brooks, 2004 USA 14744277 | >80% | RCT | 85 | 43 | 42 | 4y | Any stroke/TIA | RR | Non-estimable^†^ | | | B

RCT, randomized controlled trial; NRCS, nonrandomized comparative study; retro, retrospective; prosp, prospective; CEA, carotid endarterectomy; CAS, carotid artery stenting; CAD, coronary artery disease; DM, diabetes mellitus; TIA, transient ischemic attack; nd, no data; HR, hazard ratio; RR, relative risk

* Calculated from raw events

† RR cannot be estimated since no events occurred in both arms.

Appendix E. Table 16 Comparison of CAS versus CEA for different durations of follow-up

Author, Year Country PMID | Design | Total (n) | CAS (n) | CEA (n) | Followup | Outcome | Metric^*^ | Result | 95 % CI | P btw | Study quality
Yadav 2004, Gurm 2008, USA 15470212; 18403765 | RCT | 237 | 117 | 120 | 1y | Any periprocedural stroke, MI, or death or postprocedural ipsilateral stroke | RR^*^ | 0.47 | 0.25 - 0.89 | 0.021 | A
Yadav 2004, Gurm 2008, USA 15470212; 18403765 | RCT | 237 | 117 | 120 | 3y | Any periprocedural stroke, MI, or death or postprocedural ipsilateral stroke | RR^*^ | 0.73 | 0.46 - 1.14 | 0.171 | A

RCT, randomized controlled trial; NRCS, nonrandomized comparative study; retro, retrospective; prosp, prospective; CEA, carotid endarterectomy; CAS, carotid artery stenting; CAD, coronary artery disease; DM, diabetes mellitus; TIA, transient ischemic attack; nd, no data; HR, hazard ratio; RR, relative risk

* Calculated from raw events

Appendix E. Table 17 Comparison of CAS versus CEA for the outcome of periprocedural cerebrovascular events

Author, Year Country PMID | Design | Total (n) | CAS (n) | CEA (n) | Age (y) | male (%) | CAD (%) | DM (%) | % ≥ 70% stenosis | Followup | Outcome | Metric^*^ | Result | 95 % CI | P btw | Study quality
CREST, 2010; 2011 USA 20505173; 21307169 | RCT | 1181 | 594 | 587 | 69.3 | 65.6 | 49.7 | 33.1 | 92.3 | 30 days | Any stroke | HR^*^ | 1.88 | 0.79,4.42 | 0.15 | A
Brooks, 2004 USA 14744277 | RCT | 85 | 43 | 42 | 68.2 | nd | 64.5 | 14 | 100 | 30 days | Any stroke / TIA | RR | Non-estimable^†^ | | | B
Yadav 2004, Gurm 2008, USA 15470212; 18403765 | RCT | 237 | 117 | 120 | 72.5 | 67 | 80.0 | 26.0 | 100 | 30 days | Any stroke | RR^‡^ | 1.54 | 0.44 -5.31 | 0.496 | B
Yadav 2004, Gurm 2008, USA 15470212; 18403765 | RCT | 237 | 117 | 120 | 72.5 | 67 | 80.0 | 26.0 | 100 | 30 days | Ipsilateral stroke | RR^‡^ | 1.71 | 0.42-6.99 | 0.456 | B
CaRESS, 2005 2009, USA, 16102616;19702339 | NRCS, prosp | 269 | 99 | 170 | 71.3 | 62 | 63 | 26 | 91 | 30 days | Any stroke | RR^‡^ | 0.57 | 0.06, 5.42 | 0.627 | B
De Rango, 2011, Italy 21292127 | NRCS, prosp | 1518 | 816 | 702 | nd | nd | nd | nd | nd | 2.8y | Any periprocedural stroke or death | OR | 1.5 | 0.71-3.17 | 0.36 | C
Marine, 2006 1434877 USA | NRCS, retro | 238 | 93 | 145 | 69.7 | 61.9 | 68.2 | 35.5 | 100% | 30 days | Any stroke | RR^‡^ | 0.52 | 0.05, 4.92 | 0.568 | C
McPhee, 2008 USA 18829236 | NRCS, retro^§^ | 122,986 | 11,302 | 111,684 | 71.1 | 57.7 | 11.1 | 26.6 | nd | in-hospital (<30 days) | Any stroke | RR^‡^ | 1.82 | 1.55, 2.12 | <0.0001 | C
McPhee, 2007 USA 18154987 | NRCS, retro^§^ | 238,389 | 12278 | 226111 | 71.2 | 57 | 11.8 | 25.4 | nd | in-hospital (<30 days) | Any stroke | RR ‡ | 2.09 | 1.82, 2.40 | <0.0001 | C
Sidawy, 2009 USA 19028045 | NRCS, retro^§^ | 1667 | 805 | 862 | 71 | 59.6 | 54 | 30 | nd | 30 days | Any stroke | RR^‡^ | 1.65 | 0.77, 3.51 | 0.189 | C
Sidawy, 2009 USA 19028045 | NRCS, retro^§^ | 1667 | 805 | 862 | 71 | 59.6 | 54 | 30 | nd | 30 days | TIA | RR^‡^ | 3.21 | 1.04, 9.91 | 0.042 | C
Giacovelli, 2010 USA 20620010 | NRCS, retro^§^ | 8706 | 4354 | 4354 | 71.7 | 60.1 | 48.1 | 29.2 | nd | <30 days | Any stroke | RR^‡^ | 1.17 | 0.86, 1.58 | 0.307 | C

RCT, randomized controlled trial; NRCS, nonrandomized comparative study; retro, retrospective; prosp, prospective; CEA, carotid endarterectomy; CAS, carotid artery stenting; CAD, coronary artery disease; DM, diabetes mellitus; TIA, transient ischemic attack; nd, no data; HR, hazard ratio; RR, relative risk

* Adjusted for age and sex

† RR cannot be estimated since no events occurred in both arms.

‡ Calculated from raw data;

§ Administrative dataset

Appendix E. Table 18 Comparison of CAS versus CEA for the outcome of periprocedural mortality

Author, Year Country PMID | Design | Total (n) | CAS (n) | CEA (n) | Age (y) | male (%) | CAD (%) | DM (%) | % ≥ 70% stenosis | Followup | Outcome | Metric^*^ | Result | 95 % CI | P btw | Study quality
Yadav 2004, Gurm 2008, USA 15470212; 18403765 | RCT | 237 | 117 | 120 | 72.5 | 67 | 80.0 | 26.0 | 100 | 30 days | Death | RR^†^ | 2.05 | 0.18 -22.3 | 0.555 | B
CaRESS, 2005 2009, USA, 16102616;19702339 | NRCS, prosp | 269 | 99 | 170 | 71.3 | 62 | 63 | 26 | 91 | 30 days | Death | RR | Non-estimable | | | B
Marine, 2006 1434877 USA | NRCS, retro | 238 | 93 | 145 | 69.7 | 61.9 | 68.2 | 35.5 | 100% | 30 days | Death | RR^†^ | 1.56 | 0.09, 24.6 | 0.752 | C
McPhee, 2008 USA 18829236 | NRCS, retro^*^ | 122,986 | 11,302 | 111,684 | 71.1 | 57.7 | 11.1 | 26.6 | nd | in-hospital (<30 days) | Death | RR^†^ | 1.49 | 1.14, 1.93 | 0.003^‡^ | C
McPhee, 2007 USA 18154987 | NRCS, retro^*^ | 238,389 | 12278 | 226111 | 71.2 | 57 | 11.8 | 25.4 | nd | in-hospital (<30 days) | Death | RR^†^ | 1.29 | 0.98, 1.70 | 0.067 | C
Sidawy, 2009 USA 19028045 | NRCS, retro^*^ | 1667 | 805 | 862 | 71 | 59.6 | 54 | 30 | nd | 30 days | Death | RR^†^ | 2.86 | 1.12, 7.26 | 0.028 | C
Giacovelli, 2010 USA 20620010 | NRCS, retro^*^ | 8706 | 4354 | 4354 | 71.7 | 60.1 | 48.1 | 29.2 | nd | <30 days | Death | RR^§^ | 1.41 | 0.75, 2.62 | 0.276 | C

RCT, randomized controlled trial; NRCS, nonrandomized comparative study; retro, retrospective; prosp, prospective; CEA, carotid endarterectomy; CAS, carotid artery stenting; CAD, coronary artery disease; DM, diabetes mellitus; TIA, transient ischemic attack; nd, no data; HR, hazard ratio; RR, relative risk

* Administrative dataset

† Calculated from raw data

‡ Contrary to the reported p-value in the paper, our calculations showed statistical significance

§ Adjusted for age, sex, hospital teaching type, year of procedure, payer status, coronary artery disease/previous MI, congestive heart failure, valvular heart disease, diabetes mellitus, chronic lung disease, hypertension, renal failure, and obesity

Appendix E. Table 19 Comparison of CAS versus CEA for the outcome of periprocedural MI

Author, Year Country PMID | Design | Total (n) | CAS (n) | CEA (n) | Age (y) | male (%) | CAD (%) | DM (%) | % ≥ 70% stenosis | Followup | Outcome | Metric^*^ | Result | 95 % CI | P btw | Study quality
Brott, 2010 USA 20505173 | RCT | 1181 | 594 | 587 | 69.3 | 65.6 | 49.7 | 33.1 | 92.3 | 30 days | MI | HR^*^ | 0.55 | 0.22,1.38 | 0.2 | A
Yadav 2004, Gurm 2008, USA 15470212; 18403765 | RCT | 237 | 117 | 120 | 72.5 | 67 | 80.0 | 26.0 | 100 | 30 days | MI | RR^†^ | 0.38 | 0.10 - 1.41 | 0.150 | B
CaRESS, 2005 2009, USA, 16102616;19702339 | NRCS, prosp | 269 | 99 | 170 | 71.3 | 62 | 63 | 26 | 91 | 30 days | MI | RR^†^ | 0.43 | 0.01, 9.42 | 0.592 | B
Marine, 2006 1434877 USA | NRCS, retro | 238 | 93 | 145 | 69.7 | 61.9 | 68.2 | 35.5 | 100 | 30 days | MI | RR^†^ | 0.78 | 0.07, 8.47 | 0.838 | C
McPhee, 2007 USA 18154987 | NRCS, retro^‡^ | 238,389 | 12278 | 226111 | 71.2 | 57 | 11.8 | 25.4 | nd | in-hospital (<30 days) | MI | RR^†^ | 1.18 | 1.04, 1.35 | 0.012 | C
Sidawy, 2009 USA 19028045 | NRCS, retro^‡^ | 1667 | 805 | 862 | 71 | 59.6 | 54 | 30 | nd | 30 days | MI | RR^†^ | 2.36 | 0.82, 6.75 | 0.111 | C

RCT, randomized controlled trial; NRCS, nonrandomized comparative study; retro, retrospective; prosp, prospective; CEA, carotid endarterectomy; CAS, carotid artery stenting; CAD, coronary artery disease; DM, diabetes mellitus; TIA, transient ischemic attack; nd, no data; HR, hazard ratio; RR, relative risk

* Adjusted for age and sex

† Calculated from raw data

‡ Administrative dataset

Appendix E. Table 20 Comparison of CAS versus CEA for periprocedural composite outcomes

Author, Year Country PMID | Design | Total (n) | CAS (n) | CEA (n) | Age (y) | male (%) | CAD (%) | DM (%) | % ≥ 70% stenosis | Followup | Outcome | Metric^*^ | Result | 95 % CI | P btw | Study quality
Brott, 2010 USA 20505173 | RCT | 1181 | 594 | 587 | 69.3 | 65.6 | 49.7 | 33.1 | 92.3 | 30 days | Any stroke, MI, or death | HR^*^ | 1.02 | 0.55,1.86 | 0.96 | A
Brott, 2010 USA 20505173 | RCT | 1181 | 594 | 587 | 69.3 | 65.6 | 49.7 | 33.1 | 92.3 | 30 days | Any stroke or death | HR^*^ | 1.88 | 0.79,4.42 | 0.15 | A
Yadav 2004, Gurm 2008, USA 15470212; 18403765 | RCT | 237 | 117 | 120 | 72.5 | 67 | 80.0 | 26.0 | 100 | 30 days | Any stroke, MI, or death | RR^†^ | 0.51 | 0.19, 1.32 | 0.167 | A
Yadav 2004, Gurm 2008, USA 15470212; 18403765 | RCT | 237 | 117 | 120 | 72.5 | 67 | 80.0 | 26.0 | 100 | 30 days | Any stroke or death | RR^§^ | 1.44 | 0.47-4.40 | 0.526 | B
CaRESS, 2005 2009, USA, 16102616;19702339 | NRCS, prosp | 269 | 99 | 170 | 71.3 | 62 | 63 | 26 | 91 | 30 days | Any stroke or death | RR^†^ | 0.57 | 0.06, 5.42 | 0.627 | B
CaRESS, 2005 2009, USA, 16102616;19702339 | NRCS, prosp | 269 | 99 | 170 | 71.3 | 62 | 63 | 26 | 91 | 30 days | Any stroke or death or MI | RR^†^ | 0.34 | 0.03, 2.92 | 0.324 | B
Marine, 2006 1434877 USA | NRCS, retro | 238 | 93 | 145 | 69.7 | 61.9 | 68.2 | 35.5 | 100 | 30 days | Any stroke or death | RR^†^ | 1.04 | 0.17, 6.10 | 0.966 | C
Bosiers, 2005 15996363 Belgium | NRCS, retro | 79 | 59 | 20 | nd | nd | nd | nd | 100 | 30 days | Any stroke or death | RR^†^ | 1.02 | 0.04, 23.9 | 0.992 | C
Sidawy, 2009 USA 19028045 | NRCS, retro^‡^ | 1667 | 805 | 862 | 71 | 59.6 | 54 | 30 | nd | 30 days | Any stroke, death or MI | RR^†^ | 2.33 | 1.32, 4.10 | 0.003 | C
Giacovelli, 2010 USA 20620010 | NRCS, retro^‡^ | 8706 | 4354 | 4354 | 71.7 | 60.1 | 48.1 | 29.2 | nd | <30 days | Any stroke or death | RR^†^ | 1.23 | 0.92, 1.63 | 0.161 | C
Lindstrom, 2012, Sweden, 22342694 | NRCS, retro^‡^ | 1416 | 101 | 1315 | nd | nd | nd | nd | nd | 30 day | Any stroke or death | RR^†^ | 2.70 | 1.46, 5.01 | 0.002 | C

RCT, randomized controlled trial; NRCS, nonrandomized comparative study; retro, retrospective; prosp, prospective; CEA, carotid endarterectomy; CAS, carotid artery stenting; CAD, coronary artery disease; DM, diabetes mellitus; TIA, transient ischemic attack; nd, no data; HR, hazard ratio; RR, relative risk

* Adjusted for age and sex

† Calculated from raw data

‡ Administrative dataset

§ Calculated from raw data as provided in the FDA website

Appendix E. Table 21 Comparison of CAS versus CEA for the outcome of periprocedural cranial nerve palsy

Author, Year Country PMID | Design | Total (n) | CAS (n) | CEA (n) | Age (y) | male (%) | CAD (%) | DM (%) | % ≥ 70% stenosis | Followup | Outcome | Metric^*^ | Result | 95 % CI | P btw | Study quality
Brott, 2010; Silver 2011 USA 20505173; 21307169 | RCT | 1181 | 594 | 587 | 69.3 | 65.6 | 49.7 | 33.1 | 92.3 | 30 days | Cranial Nerve Palsy | RR^*^ | 0.04 | 0.00, 0.29 | 0.002 | A
Brooks, 2004 USA 14744277 | RCT | 85 | 43 | 42 | 68.2 | nd | 64.5 | 14 | 100 | 30 days | Cranial Nerve Palsy | RR^*^ | 0.14 | 0.00, 2.61 | 0.188 | B
Marine, 2006 1434877 USA | NRCS, retro | 238 | 93 | 145 | 69.7 | 61.9 | 68.2 | 35.5 | 100% | 30 days | Cranial nerve palsy | RR^*^ | 0.17 | 0.00, 3.18 | 0.238 | C
Giacovelli, 2010 USA 20620010 | NRCS, retro^†^ | 8706 | 4354 | 4354 | 71.7 | 60.1 | 48.1 | 29.2 | nd | <30 days | Cranial Nerve Palsy | RR | 0.47 | 0.21 - 1.04 | 0.064 | C

RCT, randomized controlled trial; NRCS, nonrandomized comparative study; retro, retrospective; prosp, prospective; CEA, carotid endarterectomy; CAS, carotid artery stenting; CAD, coronary artery disease; DM, diabetes mellitus; TIA, transient ischemic attack; nd, no data; HR, hazard ratio; RR, relative risk

* Calculated from raw data

† Administrative dataset

Appendix E. Table 22 Comparison of CAS versus CEA for periprocedural bleeding complications

Author, Year Country PMID | Design | Total (n) | CAS (n) | CEA (n) | Age (y) | male (%) | CAD (%) | DM (%) | % ≥ 70% stenosis | Followup | Outcome | Metric^*^ | Result | 95 % CI | P btw | Study quality
Brott, 2010; Silver 2011 USA 20505173; 21307169 | RCT | 1181 | 594 | 587 | 69.3 | 65.6 | 49.7 | 33.1 | 92.3 | 30 days | Bleeding (requiring transfusion) | RR^*^ | 1.13 | 0.41 - 3.09 | 0.813 | A
Brott, 2010; Silver 2011 USA 20505173; 21307169 | RCT | 1181 | 594 | 587 | 69.3 | 65.6 | 49.7 | 33.1 | 92.3 | 30 days | Hematoma | RR^*^ | 4.94 | 0.23 - 102. | 0.302 | A
Marine, 2006 1434877 USA | NRCS, retro | 238 | 93 | 145 | 69.7 | 61.9 | 68.2 | 35.5 | 100% | 30 days | Hematoma | RR^*^ | 1.30 | 0.40, 4.13 | 0.658 | C
Giacovelli, 2010 USA 20620010 | NRCS, retro^†^ | 8706 | 4354 | 4354 | 71.7 | 60.1 | 48.1 | 29.2 | nd | <30 days | Bleeding | RR^*^ | 0.90 | 0.72, 1.12 | 0.357 | C

RCT, randomized controlled trial; NRCS, nonrandomized comparative study; retro, retrospective; prosp, prospective; CEA, carotid endarterectomy; CAS, carotid artery stenting; CAD, coronary artery disease; DM, diabetes mellitus; TIA, transient ischemic attack; nd, no data; HR, hazard ratio; RR, relative risk

* Calculated from raw data

† Administrative dataset