# Forest plot of medical therapy alone studies

Appendix D. Figure 1 Forest plot of the meta-analysis of incidence rates of ipsilateral stroke or TIA in medical treatment studies

The studies are ordered by the last year of recruitment in each study. Year of publication is provided in parentheses.

Figure 1 is a forest plot that depicts the incidence rates of ipsilateral stroke or TIA from medical therapy alone as assessed in 19 studies. Along the left hand column, each study is listed in chronological order of recruitment closure year with each study's year of publication provided in parenthesis. The right hand column presents the incidence rate of ipsilateral stroke or TIA of each study. Overall ipsilateral stroke or TIA occurrence was 5.5 events per 100 person-years of followup with medical therapy alone or 5.5 percent per year (summary incidence rate = 0.055, 95% CI = 0.044, 0.069).

Appendix D. Figure 2 Forest plot of the meta-analysis of incidence rates of any stroke in medical treatment studies

The studies are ordered by the last year of recruitment in each study. Year of publication is provided in parentheses.

Figure 2 is a forest plot that depicts the incidence rates of any stroke from medical therapy alone as assessed in 17 studies. Along the left hand column, each study is listed in chronological order of recruitment closure year with each study's year of publication provided in parenthesis. The right hand column presents the incidence rate of any stroke of each study. Overall any stroke occurrence was 2.6 events per 100 person-years of followup with medical therapy alone or 2.6 percent per year (summary incidence rate = 0.026, 95% CI = 0.019, 0.036).

Appendix D. Figure 3 Forest plot of the meta-analysis of incidence rates of any stroke or TIA in medical treatment studies

The studies are ordered by the last year of recruitment in each study. Year of publication is provided in parentheses.

Figure 3 is a forest plot that depicts the incidence rates of any stroke or TIA from medical therapy alone as assessed in 9 studies. Along the left hand column, each study is listed in chronological order of recruitment closure year with each study's year of publication provided in parenthesis. The right hand column presents the incidence rate of any stroke or TIA of each study. Overall any stroke occurrence was 5.6 events per 100 person-years of followup with medical therapy alone or 5.6 percent per year (summary incidence rate = 0.056, 95% CI = 0.040, 0.078).

Appendix D. Figure 4 Forest plot of the meta-analysis of incidence rates of death in medical treatment studies

The studies are ordered by the last year of recruitment in each study. Year of publication is provided in parentheses.

Figure 4 is a forest plot that depicts the incidence rates of all-cause death from medical therapy alone as assessed in 13 studies. Along the left hand column, each study is listed in chronological order of recruitment closure year with each study's year of publication provided in parenthesis. The right hand column presents the incidence rate of all-cause death of each study. Overall any stroke occurrence was 4.6 events per 100 person-years of followup with medical therapy alone or 4.6 percent per year (summary incidence rate = 0.046, 95% CI = 0.034, 0.061).