# Study Flow Diagram

Figure 1 is a flow chart that summarizes the study retrieval and selection process of articles on management of asymptomatic carotid stenosis. The literature search identified 6,052 abstracts. The abstract screening process identified 212 potentially eligible citations. The reference lists of previous systematic and narrative reviews on the topic yielded an additional 121 potentially relevant articles. Thus, a total 333 full-text articles were evaluated against the inclusion criteria. Of these, 55 studies published in 63 articles met the eligibility criteria.