# Carotid stenosis data extraction form

Appendix B.1 Medical therapy alone extraction form

Appendix B.2 Comparative studies extraction form